# Appendix A OCSPP Regulatory Requirements and Guidance

Table 2 OCSPP Regulatory Requirements for Vertebrate Animal Testing

Criteria | CFR Citation OPP | CFR Citation OPPT | Summary
Health effects | 40 CFR § 158.500 | 40 CFR § 798.2250; 40 CFR § 798.2450; 40 CFR § 798.3260; 40 CFR § 798.3300; 40 CFR § 798.3320; 40 CFR § 798.4100; 40 CFR § 798.4350; 40 CFR § 798.4700; 40 CFR § 798.4900; 40 CFR § 798.5195; 40 CFR § 798.5200; 40 CFR § 798.5385; 40 CFR § 798.5395; 40 CFR § 798.5460; 40 CFR §§ 798.6050, 798.6200; 40 CFR § 798.6400; 40 CFR § 798.6500; 40 CFR § 798.6560 | To assess and evaluate the toxic characteristics of a chemical, a variety of tests are required or conditionally required including acute toxicity, subchronic toxicity, chronic toxicity, genetic toxicity, developmental toxicity and reproductive toxicity. These studies determine the effects of a substance in mammals over periods of short-term exposure, repeated, and prolonged exposures. In addition to identify specific effects in a target organ or system (e.g. nervous system), a no-observed-effect level (NOEL), lowest-observed-effect level (LOEL), carcinogenicity effects, and dose-response relationships may be derived depending on study design. A battery of tests is required to assess a substance’s ability to alter genetic material in cells. The species selection may vary, but rats and mice are commonly recommended. Testing to determine a substances absorption, distribution, metabolism, and excretion provides mechanistic information on toxicity that can be used in risk assessment to extrapolate from animals to humans.
Environmental effects | 40 CFR § 158.630 | 40 CFR § 797.1400; 40 CFR § 797.1600 | The information required to assess hazards to organisms is derived from tests to determine a chemical substance’s effect on birds, mammals, fish, terrestrial and aquatic invertebrates, and plants. These tests include short-term acute, subacute, reproduction, simulated field, and full field studies arranged in a hierarchical or tier system that progresses from the basic laboratory tests to the applied field tests.
Chemical specific | N/A | 40 CFR Part 799 Subpart B, C, D. | This part identifies the test rules and consent agreements for specific chemical substances and mixtures to determine if those chemicals will produce adverse effects to human health or the environment. According to Subpart B, manufacturers, importers, and processors must submit the test data conducted in accordance with the study plans stipulated in this part.
Restricted use classification | 40 CFR § 152.170 (b) and (c) | N/A | An end-use pesticide intended for residential, institutional, or other uses may be deemed restricted for use by certified applicators only based on human hazard criteria using acute toxicity endpoints.; A pesticide intended for outdoor use may be considered restricted use if its residues exceed thresholds for mammalian wildlife, exposed birds, or non-target aquatic organisms based on acute dietary LC50 values and avian subacute dietary LC50 values.
Hazard and Precautionary Statements | 40 CFR § 156.62; 40 CFR § 156.85 | N/A | The four Toxicity Categories for acute hazards of pesticides are assigned for five types of acute exposure – Oral lethal dose, 50% (LD_50_), Dermal LD_50_, Inhalation LC_50_, eye irritation and skin irritation.; Hazard statements may be required for non-target organisms for pesticides intended for outdoor use based on mammalian acute oral LD_50_, fish acute LC_50_, or avian acute oral LD_50_.
Child-Resistant Packaging | 40 CFR § 157.22 | N/A | For pesticides formulated for residential use, the toxicity criteria for determining whether the product is sold in child-resistance packaging is based on the five types of acute exposure.

Table 3 Office of Pesticide Programs – Regulatory Flexibility for Incorporating NAMs

Citation | Summary | Guidance Sources
40 CFR § 158.30 Flexibility | FIFRA provides EPA flexibility to require, or not require, data and information for the purposes of making regulatory decisions for pesticide products. EPA has the authority to establish or modify data needs for individual pesticide chemicals. The actual data required may be modified on an individual basis to fully characterize the use and properties, characteristics, or effects of specific pesticide products under review. | - Guiding Principles for Data Requirements (https://www.epa.gov/pesticide-registration/guiding-principles-data-requirements) (EPA, 2013a).; - Process for evaluating and implementing alternative approaches to traditional in vivo acute toxicity studies for FIFRA regulatory use (https://www.epa.gov/sites/default/files/2016-03/documents/final_alternative_test_method_guidance_2-4-16.pdf) (EPA, 2016a).; - TWG (Q)SAR guidance document (https://www.epa.gov/sites/default/files/2016-01/documents/qsar-guidance.pdf) (NAFTA, 2012).; - Fish Bioconcentration Data Requirement Guidance (https://www.epa.gov/sites/default/files/2020-07/documents/bcf-study-july-15-2020.pdf) (EPA, 2020c); - Part 158 Toxicology Data Requirements: Guidance for Neurotoxicity Battery, Subchronic Inhalation, Subchronic Dermal and Immunotoxicity Studies (https://www.epa.gov/sites/default/files/2014-02/documents/part158-tox-data-requirement.pdf) (EPA, 2013b)
40 CFR § 158.45 Waivers | The data requirements specified in this part as applicable to a category of products will not always be appropriate for every product in that category. Some products may have unusual physical, chemical, or biological properties or atypical use patterns which would make data requirements inappropriate, either because it would not be possible to generate the required data or because the data would not be useful in the Agency’s evaluation of the risks or benefits of the product. The Agency will waive data requirements it finds are inappropriate but will ensure that sufficient data are available to make the determinations required by the applicable statutory standards. | - Guidance for Waiving Acute Dermal Toxicity Tests for Pesticide Technical Chemicals (https://www.epa.gov/sites/default/files/2021-01/documents/guidance-for-waiving-acute-dermal-toxicity.pdf) (EPA, 2020d); - Final Guidance for Waiving Sub-Acute Avian Dietary Tests (https://www.epa.gov/sites/default/files/2020-02/documents/final-waiver-guidance-avian-sub-acute-dietary.pdf) (EPA, 2020e); - Guidance for Waiving Acute Dermal Toxicity Tests for Pesticide Formulations (https://www.epa.gov/sites/default/files/2016-11/documents/acute-dermal-toxicity-pesticide-formulations_0.pdf) (EPA, 2016b); - Guidance for Waiving or Bridging of Mammalian Acute Toxicity Tests (https://www.epa.gov/sites/default/files/documents/acute-data-waiver-guidance.pdf) (EPA, 2012)