# List Of Acronyms

CAA: Clean Air Act
CCL: Contaminant Candidate List
CERCLA: Comprehensive Environmental Response, Compensation, and Liability Act
CFR: Code of Federal Regulations
CWA: Clean Water Act
EDSP: Endocrine Disruptor Screening Program
EPA: Environmental Protection Agency
ESA: Endangered Species Act
FFDCA: Federal Food, Drug, and Cosmetic Act
FIFRA: Federal Insecticide, Fungicide, and Rodenticide Act
FQPA: Food Quality Protection Act
ICCVAM: Interagency Coordinating Committee on the Validation of Alternative Methods
IRIS: Integrated Risk Information System
MOA: Mode of Action
NAM: New Approach Method
OCSPP: Office of Chemical Safety and Pollution Prevention
OECD: Organisation for Economic Co-operation and Development
OPP: Office of Pesticide Programs
OPPT: Office of Pollution Prevention and Toxics
ORD: Office of Research and Development
OW: Office of Water
PFAS: Per- and Polyfluoroalkyl Substances
RfC/RfD: Reference Concentration or Dose
QSAR: Quantitative Structure-Activity Relationship
RCRA: Resource Conservation and Recovery Act
SAR: Structure-Activity Relationships
SDWA: Safe Drinking Water Act
SNAP: Significant New Alternatives Policy
TSCA: Toxic Substances Control Act
URE: Unit Risk Estimate
WET: Whole Effluent Toxicity
WoE: Weight-of-Evidence