# Acknowledgments

[underlined: Executive Leadership Team]

- Michael Regan
  Michal Freedhoff
  Chris Frey
  Jake Li
  Wayne Cascio

[underlined: Work Plan Leadership Team]

- Tala Henry
  Russell Thomas
  Anna Lowit
  Krystle Yozzo
  Evisabel Craig
  Monique Perron
  Susanna Blair
  Annette Guiseppi-Elie
  Monica Linnenbrink
  Nisha Sipes

## Work Plan Development and Writing Team Subgroups

[underlined: Regulatory Flexibility and Existing Statutes]

- Gino Scarano^*^
  Susan Burden
  Jan Matuskzo
  Dan Chang
  Shannon Rebersak
  Betsy Behl
  Louis D’Amico

[underlined: Baselines and Metrics]

- Evisabel Craig^*^
  Jaimie Graff
  David Diaz-Sanchez
  Martin Phillips
  Chantel Nicolas
  Kristan Markey

[underlined: Scientific Confidence and Demonstration]

- Monique Perron^*^
  Katie Paul-Friedman
  Mike Devito
  Ed Odenkirchen
  Kellie Fay
  William Irwin
  David Bussard
  Samantha Jones
  Stiven Foster

[underlined: NAM Development and Scientific Gaps]

- Maureen Gwinn^*^
  Joshua Harrill
  Anna Lowit
  Jone Corrales
  Sarah Gallagher
  Bill Wooge
  Allison Crimmins
  Kathleen Raffaele

[underlined: Communication and Outreach]

- Monica Linnenbrink^*^
  Anna Champlin
  Steven Snyderman
  Susanna Blair
  Cheryl Dunton
  Nisha Sipes

* Subgroup lead