# Summary and Next Steps

EPA will continue its leadership role to develop the science and policies necessary to reduce its reliance on vertebrate animal testing as expeditiously as possible while remaining true to the Agency’s mission of protecting public health and the environment. This updated work plan is an important milestone in this endeavor and the objectives, strategies, and deliverables provide a roadmap towards accomplishing the goal. However, like any roadmap, the work plan represents a snapshot in time. This document will need to continue to evolve as EPA’s knowledge and experience grows. The Agency is committed to regularly reviewing the work plan to ensure that the objectives, strategies, and deliverables provide the best possible path to success.

Although the work plan is confined to the Agency’s authority and associated activities, success will not be possible without the involvement of external partners, stakeholders and the broader scientific community. EPA has been heavily involved in multiple domestic and international organizations developing, evaluating, and applying NAMs such as the ICCVAM, Tox21, Accelerating the Pace of Chemical Risk Assessment (APCRA) inter-governmental workshops, and OECD. EPA will continue to engage in these efforts. Other U.S. federal agencies and international regulatory bodies are undertaking similar initiatives and the private sector continues to apply new methods and technologies to product development. The sharing of experience, information, and approaches will accelerate efforts to use the best available science in assessing the potential risks of a chemical.

Through this work plan, the Agency is creating a new paradigm for chemical risk assessment while ensuring transparency and accountability. Federal partners, stakeholders and the public at large will be able to track EPA’s progress in meeting each of the objectives identified in this work plan and ensure that the methods being applied remain fully protective of human health and the environment. As the Agency continues to implement the work plan it is important to remember that a plan is meaningless without action.