# V Engage and Communicate with Stakeholders

The information and data resulting from NAMs have the capacity to replace vertebrate animal testing, while still protecting public health and the environment. However, the wide-spread use and reliance on NAMs in Agency decisions requires a fundamental change in thinking for regulators, the regulated community, the scientific and technical community, and other stakeholders. Changes of this magnitude are difficult as traditional approaches have been used for decades in both national and international regulatory decisions. Effective engagement and communication with stakeholders are essential to increase acceptance, obtain constructive feedback, and improve the acceptance of using NAMs to inform Agency decisions.

## Strategy, Deliverables, and Timeline

The strategy involves communicating and engaging with internal Agency partners as well as external stakeholders throughout the development and implementation of the NAMs work plan. The strategy ensures that important information on EPA’s NAMs efforts is available and stakeholders are engaged in each step. EPA will place an emphasis on communications and engagement as important milestones of EPA’s NAMs efforts are reached and how the work plan evolves as EPA’s knowledge and experience grows. For example, milestones will be communicated as the work plan deliverables progress or evolve, and during the EPA NAMs conferences. The communication and engagement activities will be tailored to reach a wide variety of stakeholder groups and provide numerous opportunities for engagement.

## EPA Central Website for NAMs Information

EPA will continue to release NAMs informational materials and updates through the EPA NAMs website (https://www.epa.gov/nam). This online resource provides a mechanism for EPA to distribute NAM information including the baselines and metrics on how the effort is progressing; a portal to access informational materials such as fact sheets, conference reports, webinars; and a mechanism for stakeholders to provide feedback.

Deliverable: EPA website to house information about NAM efforts and progress being upon release of the work plan

## Solicit comment and feedback associated with deliverables

Public feedback and expert scientific review are essential to this work plan and associated deliverables. EPA will request stakeholder and public feedback on deliverables associated with the work plan through public webinars and other mechanisms. In addition, EPA will solicit expert review and input, where appropriate, through groups such as the National Academies of Science, EPA’s Science Advisory Board, EPA’s Board of Scientific Counselors, and other EPA scientific advisory groups.

Deliverable: Public webinars and, peer-review where appropriate, on deliverables from the work plan. This is an ongoing deliverable.

## Develop training courses, workshops, and conferences for stakeholders on NAMs

Training courses, workshops, and conferences are vital to help reduce the use of vertebrate animals in assessing the potential risks of a chemical. Stakeholders want to understand how to use NAMs and their knowledge is needed to inform how NAMs can be applied. As more stakeholders learn how to use NAMs, they will become more comfortable with using them to inform regulatory decisions. EPA is performing a pilot study to develop NAMs training courses and materials. Based on the results of the pilot study, EPA will develop and organize regular training opportunities on NAMs across a broad range of stakeholder communities as well as continue efforts to inform stakeholders through sessions at regularly scheduled conferences and EPA hosted workshops, such as EPA's NAMs conference, which will provide progress updates and solicit stakeholder feedback. In addition, there are numerous ongoing training efforts already offered by other organizations (e.g., professional societies, universities, other federal agencies). Since these ongoing efforts already have existing training in place, EPA may partner with these organizations to be able to offer trainings to a wide range of stakeholder groups. Feedback received from stakeholders and collaborations with external entities demonstrating how information from NAMs can be applied will be used to refine and improve communication and engagement with stakeholders as EPA's NAMs efforts progress.

Deliverable: Complete NAMs pilot training program in the fourth quarter (Q4) of 2023 and provide regular scientific exchanges and progress updates through Agency-sponsored and partner organized events.