# IV Develop NAMs to Address Scientific Challenges and Fill Important Information Gaps

While considerable progress is being made in developing NAMs, there are still scientific challenges and information gaps that limit a complete reliance on NAMs for Agency decisions related to the assessment of a chemical’s potential risk to human health and the environment. Examples of these scientific challenges and gaps include inadequate coverage of potential biological targets and pathways, reduced or distinct xenobiotic metabolism in in vitro test systems, limited capabilities to represent the complex cellular, tissue, organ, and organism-level interactions, and a lack of robust integrated approaches to testing and assessment (IATAs)^21^ for higher tier endpoints of concern (e.g., development and reproductive toxicity). Although all these challenges do not apply to every situation and may not need to be addressed in order to apply NAMs to particular regulatory decisions, continued refinement and development of NAMs will be required for the Agency to continue making progress on reducing vertebrate animal testing.

## Strategy, Deliverables, and Timeline

In order to refine and develop NAMs that address both the myriad of Agency decisions and ways that chemicals can impact human health and the environment, a two-part strategy was developed that facilitates joint planning of NAM development by EPA research scientists and regulators as well as encourages development and dissemination of NAMs by external parties. The strategy ensures the NAMs being developed will meet the needs of end users for a specific context of use and provide an acceptable level of uncertainty, while also opening opportunities for innovation by scientists from academia, industry, and public interest organizations.

## NAM development through EPA research planning and implementation

As part of the ORD research planning process, NAM refinement and development will begin with problem formulation and include teams of EPA research scientists and regulators (Figure 2). Well-constructed problem formulation is an important component of determining the appropriate use of NAMs by helping to identify research questions, ultimate goals for NAM use, and define levels of uncertainty that may be acceptable within the context of use. For integration into Agency decisions, matching the type and certainty of information provided by a NAM (or set of NAMs) with the type and certainty of information needed for a given decision is an important consideration. This concept ensures that data and information associated with the research are ‘fit-for-purpose.’ Initial development of a NAM focuses primarily on data collection and data integration where it may be combined with other NAMs as part of a weight of evidence approach, such as an IATA or defined approach.^22^ Once developed, the NAM or combination of NAMs can be applied in case studies to evaluate their performance, define their applicability domain, and identify data gaps within the scientific confidence framework. This process may be iterative as additional information and lessons learned in the case studies are incorporated. When sufficiently mature, these NAM or combination of NAMs may then be applied to regulatory decision making. The ORD research associated with the planning process is outlined at a high level in the Strategic Research Action Plans.^23^ Research products such as peer reviewed publications, tools, or data sets that communicate the methods and results or facilitate application of the NAMs are an integral part of the process.

Figure 2 Problem-focused research planning and implementation process at EPA.

Deliverable: EPA Strategic Research Action Plans outlining research products to develop and apply NAMs. The next EPA Strategic Research Action Plans will be delivered in the first quarter (Q1) of 2023.

## Encourage NAM development and evaluation by external entities

NAM development and evaluation by external entities leverages a large pool of resources, experience, and expertise that is not directly available to the Agency. Tapping into this pool more rapidly closes important information gaps and accelerates movement toward achieving an overall reduction in the use of vertebrate animals in testing. EPA has been working actively with numerous external groups, including other U.S. government agencies, animal welfare groups, industry representatives, academia, and international organizations, to encourage the development and evaluation of NAMs. One example of EPA encouraging the development of NAMs by external entities is the award of $4.25 million to five universities through its Science to Achieve Results (STAR) Program to reduce, refine, and/or replace vertebrate animal testing in chemical hazard assessment.

Deliverable: Encourage development of NAMs through mechanisms such as the STAR program and facilitate partnerships with organizations focused on establishing scientific confidence in alternative methods. This is an ongoing deliverable.

21 OECD. Guidance Document on the Reporting of Defined Approaches to be Used Within Integrated Approaches to Testing and Assessment (https://www.oecd.org/publications/guidance-document-on-the-reporting-of-defined-approaches-to-be-used-within-integrated-approaches-to-testing-and-assessment-9789264274822-en.htm) (April 2017).

22 OECD. Guidance Document on the Reporting of Defined Approaches to be Used Within Integrated Approaches to Testing and Assessment (https://www.oecd.org/publications/guidance-document-on-the-reporting-of-defined-approaches-to-be-used-within-integrated-approaches-to-testing-and-assessment-9789264274822-en.htm) (April 2017).

23 EPA. Strategic Research Action Plans 2019-2022 (https://www.epa.gov/research/strategic-research-action-plans-2019-2022).