# III Establish Scientific Confidence in NAMs and Demonstrate Application to Regulatory Decisions

As described above, EPA’s statutes and regulations regarding chemicals span a wide range of decision contexts. Examples of these decisions include prioritization, classification and labeling, alternatives assessment, and risk assessment. In many cases, vertebrate animal tests, directly and indirectly, provide the information by which many of these decisions are made. The scientific confidence associated with the traditional toxicity tests comes from the decades of experience in their development and application. In the transition from the reliance on the vertebrate animal tests to the application of the NAMs across the range of decisions, EPA needs to continually build more scientific confidence in information from NAMs while also establishing the appropriate expectations for their performance and demonstrating their application to regulatory decisions.

## Strategy, Deliverables, and Timeline

In order to establish scientific confidence in NAMs and demonstrate application to regulatory decisions, a three-part strategy was developed that (1) characterizes the scientific quality and relevance of existing vertebrate animal tests; (2) develops recommended reporting requirements; and (3) demonstrates application of the NAMs to regulatory decisions through case studies. The strategy establishes appropriate expectations for NAMs while ensuring transparency and consistency and the education of staff and stakeholders through a process of ‘learning by doing’.

## Characterize scientific quality and relevance of traditional toxicity tests

Section 4(h)(2) of TSCA notes the need for information of "equivalent or better" scientific quality and relevance to vertebrate animal test-based results. This requirement implies that the scientific quality and relevance of the existing toxicity tests should be considered to understand the strengths and limitations of the existing models, as well as NAMs under development. The amount and type of analyses needed will depend on the NAM being developed, the adverse outcome of interest, and information available. For example, the inherent variability in traditional toxicity tests may limit the predictivity that could be achieved in any comparison. Furthermore, differences between laboratory animals and humans can impact the ability of these models to predict human health effects. As such, it may not always be appropriate to compare NAMs to traditional toxicity tests. EPA will need to focus on the mechanistic and/or biological relevance of the NAM for the hazard being assessed and potential uncertainties both with respect to and independent of the existing toxicity testing model. Although existing studies have evaluated important components associated with characterizing scientific quality and relevance, such as variability and human concordance, no authoritative study has been developed that can inform expectations for NAMs. The expectations will be incorporated into the scientific confidence framework in the subsequent deliverable.

Deliverable: U.S. National Academies of Sciences, Engineering, and Medicine study that evaluates the variability and relevance of existing mammalian toxicity tests and reviews frameworks for validation and establishing scientific confidence in testing methods. The study is funded by the EPA, but the timing is determined by the National Academies and is currently scheduled for 2023.

## Develop a scientific confidence framework to evaluate the quality, reliability, and relevance of NAMs

Historically, test methods have been validated according to principles described in guidance from the Organisation for Economic Co-operation and Development (OECD).^13^ The OECD guidance document defines validation as a process that establishes the reliability and relevance of a particular test, approach, method, or process for a specific regulatory purpose and should be flexible and adaptable. To increase flexibility to accommodate the range of decision contexts and rapid pace of NAM development, multiple entities and individuals have proposed frameworks for building confidence and accelerating the use of NAMs.^14,15,16,17^

Based on these frameworks, EPA developed a set of criteria for evaluating the scientific reliability and relevance of NAMs within TSCA and presented these criteria in the TSCA Strategic Plan.^18^ While many of the criteria in the TSCA Strategic Plan are fundamental to evaluating the quality, reliability, and relevance of NAMs, a generic framework that is applicable across EPA's myriad of statutes and regulations is also needed. The generic framework may be informed by the U.S. National Academies of Sciences, Engineering, and Medicine review of the frameworks for validation and establishing scientific confidence in testing methods and recent ICCVAM activities to revise its report on validation and regulatory acceptance of toxicological methods.

Deliverable: Scientific confidence framework to evaluate the quality, reliability, and relevance of NAMs. The framework will be released as an EPA report in the fourth quarter (Q4) of 2024.

## Develop robust reporting templates for NAMs

Studies are submitted to regulatory programs with specific reporting requirements to aid in evaluation and interpretation. To promote consistency, the OECD has general reporting templates that may be used by different regulatory jurisdictions. The templates include standard elements that should be included in methods descriptions for individual test assays, batteries of assays, and algorithms for evaluating sets of assay results. Although the reporting templates for NAMs are still evolving, the OECD has developed guidance to help standardize in vitro methods suitable for regulatory purposes^19^ as well as a reporting template for in vitro, ex vivo, or in silico tests describing molecular and cellular observations that can be relevant to the hazard assessment.^20^ To accommodate mutual acceptance of data, the EPA will build on these established templates while providing additional templates that capture the range of specific NAMs used for Agency decisions. Further, elements of the scientific confidence framework described above will be important to capture in robust reporting templates for NAMs. As such, the deliverable for the reporting templates will coincide with that for the generic framework.

Deliverable: Reporting templates which may be used by EPA and stakeholders that capture the range of specific NAMs used for Agency decisions. An initial set of reporting templates will be delivered in the fourth quarter (Q4) of 2024.

## Case studies for evaluating application to regulatory decision making for near-term and long-term application

To build on success in developing and using NAMs to date, EPA will continue to identify case studies focusing on specific questions and regulatory contexts to develop and evaluate NAMs. An initial selection of on-going case studies in EPA were identified for potential incorporation into the work plan (Table 2). Other case studies will be developed as needed to address specific data gaps and regulatory needs. Case studies will be critical for building scientific confidence in the NAMs as well as understanding their strengths and limitations across different decision contexts. The case studies will provide educational opportunities that will also help build capacity and confidence within EPA.

Table 2 Initial Selection of On-Going EPA Case Studies for Potential Incorporation into Work Plan

Title | Description
Refining Inhalation Risk Assessment with NAMs | Refine inhalation risk assessment for point of contact toxicity using a three-dimensional in vitro test system of human respiratory tissues to derive points of departure.
Integrating In Vitro Assay and Toxicokinetic Data in Read Across | Use of in vitro toxicity and toxicokinetic testing to refine/support read across categories for per- and polyfluoroalkyl substances (PFAS).
Application of In Vitro Bioactivity for Screening-Level Risk Decisions | Use of bioactivity from in vitro assays and in vitro toxicokinetics to prioritize chemical contaminants in biosolids.
Application of NAMs for Chronic and Carcinogenicity Testing | Integration of NAMs to identify chronic toxicity and non-genotoxic carcinogenicity modes-of-action and quantitative points-of-departure for regulatory decisions
Utilization of a NAM Battery for Evaluation of Developmental Neurotoxicity (DNT) Potential | Incorporation of a battery of in vitro assays that assess processes critical to the development of the nervous system into the weight of evidence evaluation of DNT potential for a chemical
Evaluating In Vitro and In Silico Toxicokinetic Approach | Evaluating the uncertainties and predictivity of in vitro and in silico toxicokinetic data and computational models

Deliverable: Case studies for evaluating application of NAMs to risk assessment and demonstrating protection of human health and the environment. Case studies will be developed and communicated through the peer-reviewed scientific literature.

13 OECD. Guidance Document on the Validation and International Acceptance of New or Updated Test Methods for Hazard Assessment (GD34) (http://www.oecd.org/officialdocuments/publicdisplaydocumentpdf/?cote=env/jm/mono(2005)14&doclanguage=en) (Aug. 18, 2005).

14 NICEATM. A Strategic Roadmap for Establishing New Approaches to Evaluate the Safety of Chemicals and Medical Products in the United States (https://ntp.niehs.nih.gov/whatwestudy/niceatm/natl-strategy/index.html) (Jan. 2018).

15 G Patlewicz (2013). Use and validation of HT/HC assays to support 21st century toxicity evaluations. 65(2):259–68. doi: 10.1016/j.yrtph.2012.12.008.

16 G Patlewicz (2015). Proposing a scientific confidence framework to help support the application of adverse outcome pathways for regulatory purposes . Regul Toxicol Pharmacol. 71(3):463–77. doi: 10.1016/j.yrtph.2015.02.01 25707856 .

17 S Casati (2018). Standardization of defined approaches for skin sensitization testing to support regulatory use and international adoption: position of the International Cooperation on Alternative Test Methods . Arch Toxicol. 92(2):611–617. doi: 10.1007/s00204-017-2097-4 29127450

18 TSCA Strategic Plan at p. 19.

19 OECD. Guidance Document on Good In Vitro Method Practice (https://www.oecd.org/env/guidance-document-on-good-in-vitro-method-practices-givimp-9789264304796-en.htm) (Dec 2018).

20 OECD. OECD Harmonised Template 201: Intermediate effects (https://www.oecd.org/ehs/templates/harmonised-templates-intermediate-effects.htm) (Dec 2018).