# II Develop Baselines and Metrics for Assessing Progress

EPA has started developing baselines and metrics to track the Agency’s progress towards its goal of reducing its use of vertebrate animals. In 2019, the United States Government Accountability Office (GAO) completed its review on issues related to alternatives to laboratory animal research at multiple federal agencies.^10^ GAO concluded that, while agencies have facilitated the development and use of alternatives to animal research, they have not “routinely developed or reported metrics that demonstrate how their efforts to encourage the use of alternative methods affect animal use.” As such, GAO recommended that EPA and the other agencies better monitor and report on their efforts to develop and promote alternative methods and decreases in laboratory animal use. In response to the report, an Interagency Coordinating Committee on the Validation of Alternative Methods (ICCVAM) workgroup found that no one set of metrics is appropriate and that metrics should be relevant, practical, and tailored to the specific needs of the organization.^11^

## Existing efforts to establish vertebrate animal use baselines across the Agency

EPA requires substantial toxicology testing to support pesticide registration. Toxicological studies in vertebrate animals are generally used to provide information on a wide range of adverse health outcomes, routes of exposure, exposure durations, species, and lifestages. The number of vertebrate animals used varies widely depending on the pesticide type and use pattern; but, between 100 and 9,000 animals are typically used for human health and ecological toxicology testing for a single pesticide.

EPA has flexibility in implementing 40 CFR Part 158 data requirements, with FIFRA allowing for waivers to be granted and alternative methods to be accepted on a case-by-case basis. By using waivers, EPA can avoid the generation of data that does not influence the scientific certainty of a regulatory decision. The number of waivers granted, and animals saved from not needing to perform repeated-dose toxicity studies, have been tracked by the OPP’s Hazard and Science Policy Council since 2012 and constitutes an important metric for vertebrate animal use reduction for EPA. Similarly, OPP has started tracking the use of waivers for acute toxicity studies.

The Endocrine Disruptor Screening Program (EDSP) established a two-tier approach to screen (Tier I) and test (Tier II) substances for perturbations to the estrogen, androgen, and thyroid systems. The Tier 1 battery of tests uses vertebrate animals and in vitro assays. Following a reorganization of OCSPP, the EDSP is now managed by OPP. The EDSP compiles the number of substances and associated tests ordered under the EDSP, which allows the number of vertebrate animals used to be tracked.

Under TSCA, the 2016 amendments added explicit requirements under section 4(h)(2) for the Agency to promote the development and incorporation of methods that reduce or replace the use of vertebrate animals, to publish a strategic plan for reducing, refining, or replacing vertebrate animal testing, and to publish a list of alternative test methods or strategies that do not require new vertebrate animals. In accordance with two elements of the TSCA Strategic Plan, OPPT has embarked on the Analysis of TSCA Available, Expected, and Potentially Useful Information (ATAEPI). This analysis will allow EPA to determine the extent of laboratory animal testing that the Agency has explicitly required companies to perform using its authority under TSCA sections 4 and 5. Once the ATAEPI project is complete, EPA will have a database of all TSCA-related studies that were conducted or made available as a result of the Agency exercising its authorities and will be able to publish metrics consisting of the number of vertebrate animal tests that were required for those tests, by year.

ORD performs research using vertebrate animals to support the Agency’s mission of protecting human health and the environment. While research performed by ORD includes studies to establish the risk parameters of various classes of compounds, ORD is also active in the development and validation of alternative methods and models that refine, reduce, and replace vertebrate animal tests. For example, ORD is evaluating the use of integrated high-throughput in vitro assays and computational modeling to identify endocrine-active compounds. Overall, the shift towards developing these new methods is expected to reduce the use of vertebrate animals in toxicology research over time.

## Strategy, Deliverables, and Timeline

Due to their regulatory roles and/or programmatic missions, OCSPP and ORD account for a significant portion of EPA’s requests for and use of vertebrate animals for toxicity testing and research. Thus, baselines and metrics for the use of vertebrate animals will be initially developed for programs within OCSPP and ORD. As other EPA offices determine their contribution to the use of vertebrate animals, their baselines and metrics will be incorporated into the overall reporting mechanisms. Due to the differences in statutory requirements and the wide range of research uses, EPA will need to establish baselines and metrics that are specific to each program, building on the existing efforts and current data gathering initiatives outlined above. EPA will communicate the results through its website and the ICCVAM biannual reports. In the past, EPA has also reported metrics for the reduction in the use of vertebrate animals via peer-reviewed publications.^12^

## Initial Baseline Calculations and Metrics

Within OCSPP, EPA will initially use the number of animals required for testing under the 40 CFR Part 158 as a baseline to measure and track use for pesticide actions. EPA will also establish a specific baseline for vertebrate animal use under TSCA once the ATAEPI analysis is completed. For the EDSP, the baseline is 1,800 animals based on the number required to complete the Tier I battery of assays. Within ORD, EPA will use the average number of mammals used for research purposes between 2016 and 2018 (8,600 per year) as an initial baseline to provide both a stable and relatively recent estimate of use. More recent estimates have been impacted by the reductions in studies during the pandemic. Over time, ORD will transition to extend the baseline to include all vertebrate animal use. OCSPP and ORD will work with other EPA offices to establish baselines and calculation methods. As additional baselines and metrics are established, EPA will distribute these estimates through the established communication mechanisms.

Deliverable: Progress and summary metrics on reducing vertebrate animal testing requests and use. The metrics will be reported annually through its website starting in the fourth quarter (Q4) of 2022.

10 GAO. Animal Use in Research: Federal Agencies Should Assess and Report on Their Efforts to Develop and Promote Alternatives (https://www.gao.gov/assets/gao-19-629.pdf) (Sep. 2019), GAO-19-629 .

11 ICCVAM. Measuring U.S. Federal Agency Progress Toward Implementation of Alternative Methods in Toxicity Testing (https://ntp.niehs.nih.gov/sites/default/files/iccvam/docs/about_docs/iccvam-measuringprogress-feb2021-fd-508.pdf) (Feb 2021).

12 E. Craig . Reducing the need for animal testing while increasing efficiency in a pesticide regulatory setting: Lessons from the EPA Office of Pesticide Programs’ Hazard and Science Policy Council (Nov. 2019). Regulatory Toxicology and Pharmacology, 108:104481. 10.1016/j.yrtph.2019.104481 31546018