# I Evaluate regulatory flexibility for accommodating the use of NAMs

EPA operates under laws and regulations which provide the authority and framework for the Agency’s regulatory and research programs. EPA implements and enforces these laws and regulations to protect human and ecological health; maintain the integrity of the nation’s air, water and land; to manage emergency response, spills and waste; and regulate pesticides and chemicals throughout the United States. In particular cases, that authority needs to be further refined or explained to accommodate the implementation of NAMs, requiring the development of rules, policies, and written guidance that represent the Agency’s interpretation or view of specific issues.

An initial review of the major environmental statutes reveals that these statutes do not prevent EPA from considering information from NAMs when carrying out its responsibilities (Table 1). Most of the statutes and regulations surveyed include statements such as the necessity of upholding scientific standards and using “the best available science,” which may include NAMs.^5^ Similarly, the authority for EPA’s research programs arising from these statutes is broadly written and does not constrain the Agency from developing or advancing the use of NAMs. For those regulations that have specific testing requirements, the Agency has been successful in using its authority to increase flexibility in some cases (e.g., using science policy changes).

Table 1 Initial Survey Results of Vertebrate Animal Testing Requirements in Major Environmental Statutes

Major Environmental Statute | Statutory Requirements for Vertebrate Animal Testing | Regulatory Requirements for Vertebrate Animal Testing
Federal Insecticide, Fungicide and Rodenticide Act (FIFRA) and Federal Food, Drug, Cosmetic Act (FFDCA) | None | 40 CFR Part 158 specifies FIFRA and FFDCA data requirements that include use of vertebrate animals (pesticide registration, registration review, and tolerance or exemptions from the requirements of a tolerance for a pesticide chemical residue).
Endangered Species Act (ESA) | None | None
Food Quality Protection Act (FQPA) amendments to the FFDCA and the Safe Drinking Water Act (SDWA) amendments | None | None^6^
Toxic Substances Control Act (TSCA) | None, but TSCA Section 4(h) requires reducing use of vertebrate animals in testing.^7^ | 40 CFR Parts 790 through 799 apply to TSCA Section 4 test rules.
Clean Air Act (CAA) | None | Fuel and Fuel Additive Registration;^8^ Significant New Alternatives Policy (SNAP) programs.^9^
Clean Water Act (CWA) | None | None
Comprehensive Environmental Response, Compensation and Liability Act (CERCLA) | None | None
Emergency Planning and Community Right-to-Know Act (EPCRA) | None | None
Resource Conservation and Recovery Act (RCRA) | None | None
Safe Drinking Water Act (SDWA) | None | None

## Strategy, Deliverables, and Timeline

To ensure a robust regulatory framework that accommodates the development and use of NAMs, EPA will expand on the initial survey and perform a thorough review of existing statutes and programmatic regulations, policies and guidance to identify vertebrate animal testing requirements that may not allow flexibility for the Agency to apply NAMs. Following the review, EPA will consider options for introducing flexibility on implementing and/or using appropriate NAMs for regulatory purposes.

Deliverable: EPA report containing a review of existing statutes, programmatic regulations, policies, and guidance that relate to vertebrate animal testing and the potential implementation and use of appropriate NAMs for regulatory purposes. The EPA report will be delivered in 2022.

5 Three examples are: (1) Per section 26 of the Toxic Substances Control Act (TSCA), the Administrator must use the “best available science” and consider “reasonably available information” when carrying out TSCA sections 4, 5, and 6. 15 U.S.C. § 2625. (2) When setting drinking water standards under the Safe Drinking Water Act (SDWA), EPA is required to use “(i) the best available, peer-reviewed science and supporting studies conducted in accordance with sound and objective scientific practices; and (ii) data collected by accepted methods or best available methods (if the reliability of the method and the nature of the decision justifies use of the data).” 42 U.S.C. § 300g-1(b)(3)(A). (3) Section 304(a) of the Clean Water Act (CWA) requires EPA to develop and publish criteria for water quality that accurately reflect the “latest scientific knowledge” and does not specify the type of toxicity data the Agency must consider. 33 U.S.C. § 1314(a).

6 Visit EPA’s Endocrine Disruptor Screening Program (https://www.epa.gov/endocrine-disruption) webpage. Also, see the EDSP Workplan for using NAMs (https://www.epa.gov/sites/default/files/2015-07/documents/edsp21_work_plan_summary_overview_final.pdf).

7 See TSCA § 4(h)(1) (stating “to the extent practicable, scientifically justified, and consistent with the policies of TSCA.”).

8 Visit EPA’s Fuels Registration, Reporting, and Compliance Help (https://www.epa.gov/fuels-registration-reporting-and-compliance-help) webpage.

9 Visit EPA’s Significant New Alternatives Policy (SNAP) Program (https://www.epa.gov/snap) webpage.