# Introduction

Evaluating and applying emerging technologies for assessing risks to human health and the environment is vital to keeping the Agency at the forefront of science and for continuing to achieve its mission. New Approach Methods (NAMs)^1^ are included among these emerging technologies and have the potential to increase the rigor and sophistication of Agency assessments while reducing the reliance on vertebrate animals to test chemicals. Reducing the use of vertebrate animals in evaluating the risks of chemicals has been identified as a priority for EPA as well as for other national and international organizations and regulatory agencies. The EPA has multiple statutory requirements and policy initiatives that prioritize reduction of animal testing (e.g., the 2018 TSCA Alternatives Strategic Plan,^2^ the Endocrine Disruptor Screening Program for the 21^st^ Century,^3^ the Office of Pesticides Program guidance on waiving acute toxicity studies^4^) and for decades the Agency has invested in developing a strong, integrated research program focused on the development and application of NAMs.

The U.S. EPA’s Office of Research and Development (ORD) and the Office of Chemical Safety and Pollution Prevention (OCSPP) were tasked with developing a work plan for reducing the use of vertebrate animals in the Agency’s regulatory, compliance, enforcement and research activities through the use of NAMs while remaining fully protective of human health and the environment. The original EPA NAMs Work Plan was released in June 2020 and laid out the Agency’s objectives and strategies. The objectives are: (1) evaluate regulatory flexibility for accommodating the use of NAMs; (2) develop baselines and metrics for assessing progress; (3) establish scientific confidence in NAMs and demonstrate application to regulatory decisions; (4) develop NAMs that fill critical information gaps; and (5) engage and communicate with stakeholders to incorporate their knowledge and address concerns (Figure 1). The Agency committed to regularly reviewing the work plan and acknowledged that the work plan would evolve as EPA’s knowledge and experience grows, and as outside experts offer their perspectives and contributions. In the updated work plan, the main objectives and strategies were left unmodified. The primary changes in the updated work plan include:

- Expansion of the species covered in the work plan to include all vertebrate animals to be consistent with TSCA.
- Modified deliverables that provide revised timelines through 2024 that reflect the expansion of covered species and incorporate feedback received over the preceding years.
- Updated scope of the U.S. National Academies of Sciences, Engineering, and Medicine study to include a review of validation and scientific confidence frameworks for NAMs in addition to evaluating the variability and relevance of existing mammalian toxicity tests.
- Two new case studies for building confidence and demonstrating application of NAMs.
- A pilot study to develop NAMs training courses and materials for a broad range of stakeholders.

Figure 1 Five work plan objectives for reducing the use of vertebrate animals in the EPA’s regulatory, compliance, enforcement and research activities while remaining fully protective of human health and the environment.

1 As defined in the Strategic Plan to Promote the Development and Implementation of Alternative Test Methods Within the TSCA Program (https://www.epa.gov/sites/production/files/2018-06/documents/epa_alt_strat_plan_6-20-18_clean_final.pdf) (June 22, 2018) (hereinafter referred to as “TSCA Strategic Plan”), a NAM is any technology, methodology, approach, or combination thereof that can be used to provide information on chemical hazard and risk assessment that avoids the use of intact animals.

2 https://www.epa.gov/sites/production/files/2018-06/documents/epa_alt_strat_plan_6-20-18_clean_final.pdf

3 https://www.epa.gov/sites/production/files/2015-07/documents/edsp21_work_plan_summary_overview_final.pdf

4 https://www.epa.gov/pesticide-registration/bridging-or-waiving-data-requirements