# Appendix

Milestones/Deliverables | Proposed Dates
Evaluate regulatory flexibility for accommodating the use of NAMs
EPA report on a review of existing statutes, programmatic regulations, policies, and guidance that relate to vertebrate animal testing and the implementation and use of appropriate NAMs for regulatory purposes. | 2022
Develop Baselines and Metrics for Assessing Progress
Progress and summary metrics on reducing vertebrate animal testing requests and use. | Annually starting in Q4 2022
Establish Scientific Confidence in NAMs and Demonstrate Application to Regulatory Decisions
U.S. National Academies of Sciences, Engineering, and Medicine study that evaluates the variability and relevance of existing mammalian toxicity tests and reviews frameworks for validation and establishing scientific confidence in testing methods. The study is funded by the EPA, but the timing is determined by the National Academies. | 2023
A scientific confidence framework to evaluate the quality, reliability, and relevance of NAMs. | Q4 2024
An initial set of reporting templates which may be used by EPA and stakeholders that capture the range of specific NAMs used for Agency decisions. | Q4 2024
Case studies for evaluating application to risk assessment and demonstrating protection of human health and the environment. | Ongoing
Develop NAMs to Address Scientific Challenges and Fill Important Information Gaps
EPA Strategic Research Action Plans outlining research products to develop and apply NAMs. | Q1 2023
Encourage development of NAMs through mechanisms such as the STAR program and facilitate partnerships with organizations focused on establishing scientific confidence in alternative methods. | Ongoing
Engage and Communicate with Stakeholders
EPA website to house information about NAM efforts and progress being upon release of the work plan. | Complete
Public webinars and, where appropriate, peer-review on deliverables from this work plan. | Ongoing
Complete NAMs pilot training program in the fourth quarter (Q4) of 2023 and provide regular scientific exchanges and progress updates through Agency sponsored and partner organized events. | Q4 2023 and Ongoing