# Abbreviations

APCRA: Accelerating Progress in Chemical Risk Assessment
ATAEPI: Analysis of TSCA Available, Expected, and Potentially Useful Information
CAA: Clean Air Act
CERCLA: Comprehensive Environmental Response, Compensation and Liability Act
CFR: Code of Federal Regulations
CWA: Clean Water Act
EDSP: Endocrine Disruptor Screening Program
EPA: Environmental Protection Agency
EPCRA: Emergency Planning and Community Right-to-Know Act
ESA: Endangered Species Act
FFDCA: Federal Food, Drug, Cosmetic Act
FIFRA: Federal Insecticide, Fungicide and Rodenticide Act
FQPA: Food Quality Protection Act
GAO: Government Accountability Office
ICCVAM: Interagency Coordinating Committee on the Validation of Alternative Methods
NAM: New Approach Method
OCSPP: Office of Chemical Safety and Pollution Prevention
OECD: Organisation for Economic Co-operation and Development
OPP: Office of Pesticide Programs
OPPT: Office of Pollution Prevention and Toxics
ORD: Office of Research and Development
PFAS: Per- and Polyfluoroalkyl Substances
RCRA: Resource Conservation and Recovery Act
SDWA: Safe Drinking Water Act
SNAP: Significant New Alternatives Policy
STAR: Science to Achieve Results
TSCA: Toxic Substances Control Act