# 5.0 References

Alloisio, S., . 2016. Microelectrode array (MEA) platform as a sensitive tool to detect and evaluate Ostreopsis cf. ovata toxicity. Harmful Algae. 55, 230–237.28073536
Alloisio, S., . 2015. Multiparametric characterisation of neuronal network activity for in vitro agrochemical neurotoxicity assessment. Neurotoxicology. 48, 152–65.25845298
Aschner, M., . 2017. Reference compounds for alternative test methods to indicate developmental neurotoxicity (DNT) potential of chemicals: example lists and criteria for their selection and use. ALTEX. 34, 49–74.27452664
Atchison, W. D., 1988. Effects of neurotoxicants on synaptic transmission: lessons learned from electrophysiological studies. Neurotoxicol Teratol. 10, 393–416.
Bal-Price, A., . 2018a. Recommendation on test readiness criteria for new approach methods in toxicology: Exemplified for developmental neurotoxicity. ALTEX. 35, 306–352.29485663
Bal-Price, A., . 2018b. Strategies to improve the regulatory assessment of developmental neurotoxicity (DNT) using in vitro methods. Toxicol Appl Pharmacol. 354, 7–18.29476865
Ball, K. R., . 2017. A multivariate extension of mutual information for growing neural networks. Neural Netw. 95, 29–43.28850900
Barenys, M., . 2017. Epigallocatechin gallate (EGCG) inhibits adhesion and migration of neural progenitor cells in vitro. Arch Toxicol. 91, 827–837.27116294
Barone, S., Jr., . 2000. Vulnerable processes of nervous system development: a review of markers and methods. Neurotoxicology. 21, 15–36.10794382
Baskar, M. K., Murthy, P. B., 2018. Acute in vitro neurotoxicity of some pyrethroids using microelectrode arrays. Toxicol In Vitro. 47, 165–177.29207333
Baumann, J., . 2016. Comparative human and rat neurospheres reveal species differences in chemical effects on neurodevelopmental key events. Arch Toxicol. 90, 1415–27.26216354
Bell, S. M., . 2018. In vitro to in vivo extrapolation for high throughput prioritization and decision making. Toxicol In Vitro. 47, 213–227.29203341
Bertrand, R., . 1994. Induction of a common pathway of apoptosis by staurosporine. Exp Cell Res. 211, 314–21.8143779
Bisio, M., . 2014. Emergence of bursting activity in connected neuronal sub-populations. PLoS One. 9, e107400.25250616
Bondy, S. C., Campbell, A., 2005. Developmental neurotoxicology. J Neurosci Res. 81, 605–12.16035107
Bradley, J. A., . 2018. In Vitro Screening for Seizure Liability Using Microelectrode Array Technology. Toxicol Sci. 163, 240–253.29432603
Bradley, J. A., Strock, C. J., 2019. Screening for Neurotoxicity with Microelectrode Array. Curr Protoc Toxicol. 79, e67.30575314
Brown, J. P., . 2016. Editor’s Highlight: Evaluation of a Microelectrode Array-Based Assay for Neural Network Ontogeny Using Training Set Chemicals. Toxicol Sci. 154, 126–139.27492221
Carr, R. L., . 2017. Decreased anxiety in juvenile rats following exposure to low levels of chlorpyrifos during development. Neurotoxicology. 59, 183–190.26642910
Carr, R. L., . 2014. Low level chlorpyrifos exposure increases anandamide accumulation in juvenile rat brain in the absence of brain cholinesterase inhibition. Neurotoxicology. 43, 82–89.24373905
Charlesworth, P., . 2015. Quantitative differences in developmental profiles of spontaneous activity in cortical and hippocampal cultures. Neural Dev. 10, 1.25626996
Cheng, C., . 2017. Highly Expandable Human iPS Cell-Derived Neural Progenitor Cells (NPC) and Neurons for Central Nervous System Disease Modeling and High-Throughput Screening. Curr Protoc Hum Genet. 92, 21 8 1–21 8 21.
Cheng, C. H., Kuchta, R. D., 1993. DNA polymerase epsilon: aphidicolin inhibition and the relationship between polymerase and exonuclease activity. Biochemistry. 32, 8568–74.8395209
Chiappalone, M., . 2006. Dissociated cortical networks show spontaneously correlated activity patterns during in vitro development. Brain Res. 1093, 41–53.16712817
Coecke, S., . 2013. Toxicokinetics as a key to the integrated toxicity risk assessment based primarily on non-animal approaches. Toxicol In Vitro. 27, 1570–7.22771339
Colombi, I., . 2013. Effects of antiepileptic drugs on hippocampal neurons coupled to micro-electrode arrays. Front Neuroeng. 6, 10.24312049
Cotterill, E., . 2016. Characterization of Early Cortical Neural Network Development in Multiwell Microelectrode Array Plates. J Biomol Screen. 21, 510–9.27028607
Crofton, K. M., . 2011. Developmental neurotoxicity testing: recommendations for developing alternative methods for the screening and prioritization of chemicals. ALTEX. 28, 9–15.21311847
Culbreth, M. E., . 2012. Comparison of chemical-induced changes in proliferation and apoptosis in human and mouse neuroprogenitor cells. Neurotoxicology. 33, 1499–1510.22634143
de Esch, C., . 2012. Zebrafish as potential model for developmental neurotoxicity testing: a mini review. Neurotoxicol Teratol. 34, 545–53.22971930
de Groot, M. W., . 2014. Characterization of calcium responses and electrical activity in differentiating mouse neural progenitor cells in vitro. Toxicol Sci. 137, 428–35.24241723
de Souza Anselmo, C., . 2018. Zebrafish (Danio rerio): A valuable tool for predicting the metabolism of xenobiotics in humans? Comp Biochem Physiol C Toxicol Pharmacol. 212, 34–46.29969680
DeGroot, D. E., . 2018. mRNA transfection retrofits cell-based assays with xenobiotic metabolism. J Pharmacol Toxicol Methods. 92, 77–94.29555536
Delp, J., . 2018. A high-throughput approach to identify specific neurotoxicants/ developmental toxicants in human neuronal cell function assays. ALTEX. 35, 235–253.29423527
Dingemans, M. M., . 2016. Chronic 14-day exposure to insecticides or methylmercury modulates neuronal activity in primary rat cortical cultures. Neurotoxicology. 57, 194–202.27720795
Druwe, I., . 2016. Comparison of Human Induced Pluripotent Stem Cell-Derived Neurons and Rat Primary Cortical Neurons as In Vitro Models of Neurite Outgrowth. Applied In Vitro Toxicology. 2, 26–26.
Druwe, I., . 2015. Sensitivity of neuroprogenitor cells to chemical-induced apoptosis using a multiplexed assay suitable for high-throughput screening. Toxicology. 333, 14–24.25841707
Duarte, D. J., . 2017. In vitro neurotoxic hazard characterization of different tricresyl phosphate (TCP) isomers and mixtures. Neurotoxicology. 59, 222–230.26851706
Einarson, A., . 2000. Prospective, controlled, multicentre study of loperamide in pregnancy. Can J Gastroenterol. 14, 185–7.10758415
Feng, G., Kaplowitz, N., 2002. Mechanism of staurosporine-induced apoptosis in murine hepatocytes. Am J Physiol Gastrointest Liver Physiol. 282, G825–34.11960779
Filer, D. L., . 2017. tcpl: the ToxCast pipeline for high-throughput screening data. Bioinformatics. 33, 618–620.27797781
Frank, C. L., . 2017. From the Cover: Developmental Neurotoxicants Disrupt Activity in Cortical Networks on Microelectrode Arrays: Results of Screening 86 Compounds During Neural Network Formation. Toxicol Sci. 160, 121–135.28973552
Frega, M., . 2012. Cortical cultures coupled to micro-electrode arrays: a novel approach to perform in vitro excitotoxicity testing. Neurotoxicol Teratol. 34, 116–27.21856414
Frega, M., . 2017. Rapid Neuronal Differentiation of Induced Pluripotent Stem Cells for Measuring Network Activity on Micro-electrode Arrays. J Vis Exp.
Fritsche, E., . 2018. Consensus statement on the need for innovation, transition and implementation of developmental neurotoxicity (DNT) testing for regulatory purposes. Toxicol Appl Pharmacol. 354, 3–6.29447839
Gao, Y., . 2004. Rational design and characterization of a Rac GTPase-specific small molecule inhibitor. Proc Natl Acad Sci U S A. 101, 7618–23.15128949
Goldstone, J. V., . 2010. Identification and developmental expression of the full complement of Cytochrome P450 genes in Zebrafish. BMC Genomics. 11, 643.21087487
Gong, X. W., . 2012. Loperamide, an antidiarrhea drug, has antitumor activity by inducing cell apoptosis. Pharmacol Res. 65, 372–8.22119769
Gordon, J. A., 1991. Use of vanadate as protein-phosphotyrosine phosphatase inhibitor. Methods Enzymol. 201, 477–82.1943774
Gorshkov, K., . 2018. Astrocytes as targets for drug discovery. Drug Discov Today. 23, 673–680.29317338
Goulian, M., . 1990. Two forms of DNA polymerase delta from mouse cells. Purification and properties. J Biol Chem. 265, 16402–11.1975812
Gramowski-Voss, A., . 2015. Enhancement of Cortical Network Activity in vitro and Promotion of GABAergic Neurogenesis by Stimulation with an Electromagnetic Field with a 150 MHz Carrier Wave Pulsed with an Alternating 10 and 16 Hz Modulation. Front Neurol. 6, 158.26236278
Grandjean, P., Landrigan, P. J., 2006. Developmental neurotoxicity of industrial chemicals. Lancet. 368, 2167–78.17174709
Grandjean, P., Landrigan, P. J., 2014. Neurobehavioural effects of developmental toxicity. Lancet Neurol. 13, 330–8.24556010
Guo, S., 2009. Using zebrafish to assess the impact of drugs on neural development and function. Expert Opin Drug Discov. 4, 715–726.19774094
Hampson, D. R., Manalo, J. L., 1998. The activation of glutamate receptors by kainic acid and domoic acid. Nat Toxins. 6, 153–8.10223631
Harrill, J. A., . 2015. Ontogeny of biochemical, morphological and functional parameters of synaptogenesis in primary cultures of rat hippocampal and cortical neurons. Mol Brain. 8, 10.25757474
Harrill, J. A., . 2018. Testing for developmental neurotoxicity using a battery of in vitro assays for key cellular events in neurodevelopment. Toxicol Appl Pharmacol. 354, 24–39.29626487
Harrill, J. A., . 2010. Quantitative assessment of neurite outgrowth in human embryonic stem cell-derived hN2 cells using automated high-content image analysis. Neurotoxicology. 31, 277–90.20188755
Harrill, J. A., . 2011a. Comparative sensitivity of human and rat neural cultures to chemical-induced inhibition of neurite outgrowth. Toxicol Appl Pharmacol. 256, 268–80.21354195
Harrill, J. A., . 2013. Use of high content image analyses to detect chemical-mediated effects on neurite sub-populations in primary rat cortical neurons. Neurotoxicology. 34, 61–73.23142577
Harrill, J. A., . 2011b. Use of high content image analysis to detect chemical-induced changes in synaptogenesis in vitro. Toxicol In Vitro. 25, 368–87.20969947
Hers, I., . 1999. The protein kinase C inhibitors bisindolylmaleimide I (GF 109203x) and IX (Ro 31–8220) are potent inhibitors of glycogen synthase kinase-3 activity. FEBS Lett. 460, 433–6.10556511
Hogberg, H. T., . 2011. Application of micro-electrode arrays (MEAs) as an emerging technology for developmental neurotoxicity: evaluation of domoic acid-induced effects in primary cultures of rat cortical neurons. Neurotoxicology. 32, 158–68.21056592
Hondebrink, L., . 2016. Neurotoxicity screening of (illicit) drugs using novel methods for analysis of microelectrode array (MEA) recordings. Neurotoxicology. 55, 1–9.27149913
Huang, T., . 2016. Microelectrode Array-evaluation of Neurotoxic Effects of Magnesium as an Implantable Biomaterial. J Mater Sci Technol. 32, 89–96.27110081
Jenkins, F., Barr, D., Chen, J., Cronin, M., Delcos, K., Ehrich, M., Georgopoulos, P., Hayton, W., Jett, D., Mcdonald, P., Mcmanaman, J., Murphy, C., Potter, T.L., Schlenk, D. , SAP Minutes No. 2014-03 for FIFRA meeting held July 29-31, 2014. A set of scientific issues being considered by the Environmental Protection Agency regarding new high throughput methods to estimate chemical exposure. . Environmental Protection Agency. , 2014.
Johnstone, A. F., . 2010. Microelectrode arrays: a physiologically based neurotoxicity testing platform for the 21st century. Neurotoxicology. 31, 331–50.20399226
Karaman, M. W., . 2008. A quantitative analysis of kinase inhibitor selectivity. Nat Biotechnol. 26, 127–32.18183025
Kasteel, E. E., Westerink, R. H., 2017. Comparison of the acute inhibitory effects of Tetrodotoxin (TTX) in rat and human neuronal networks for risk assessment purposes. Toxicol Lett. 270, 12–16.28192153
Kepiro, M., . 2018. High Content, Phenotypic Assays and Screens for Compounds Modulating Cellular Processes in Primary Neurons. Methods Enzymol. 610, 219–250.30390800
Khazipov, R., Luhmann, H. J., 2006. Early patterns of electrical activity in the developing cerebral cortex of humans and rodents. Trends Neurosci. 29, 414–418.16713634
Kirshenboim, N., . 2004. Lithium-mediated phosphorylation of glycogen synthase kinase-3beta involves PI3 kinase-dependent activation of protein kinase C-alpha. J Mol Neurosci. 24, 237–45.15456937
Kohno, R., . 2006. Sphere formation of ocular epithelial cells in the ciliary body is a reprogramming system for neural differentiation. Brain Res. 1093, 54–70.16697356
Kokel, D., . 2010. Rapid behavior-based identification of neuroactive small molecules in the zebrafish. Nat Chem Biol. 6, 231–237.20081854
Kondo, Y., . 2017. Temporal relation between neural activity and neurite pruning on a numerical model and a microchannel device with micro electrode array. Biochem Biophys Res Commun. 486, 539–544.28322793
Kosnik, M. B., . 2020. Concentration-response evaluation of ToxCast compounds for multivariate activity patterns of neural network function. Arch Toxicol. 94, 469–484.31822930
Kota, K. P., . 2012. High content image based analysis identifies cell cycle inhibitors as regulators of Ebola virus infection. Viruses. 4, 1865–77.23202445
Kreir, M., . 2018. Do in vitro assays in rat primary neurons predict drug-induced seizure liability in humans? Toxicol Appl Pharmacol. 346, 45–57.29596924
Krokan, H., . 1981. Aphidicolin inhibits DNA synthesis by DNA polymerase alpha and isolated nuclei by a similar mechanism. Nucleic Acids Res. 9, 4709–19.6795595
Krug, A. K., . 2013. Evaluation of a human neurite growth assay as specific screen for developmental neurotoxicants. Arch Toxicol. 87, 2215–31.23670202
Lantz, S. R., . 2014. Glufosinate binds N-methyl-D-aspartate receptors and increases neuronal network activity in vitro. Neurotoxicology. 45, 38–47.25268653
Lein, P., . 2007. Meeting report: alternatives for developmental neurotoxicity testing. Environ Health Perspect. 115, 764–8.17520065
Lenk, K., . 2016. Simulation of developing human neuronal cell networks. Biomed Eng Online. 15, 105.27576323
McConnell, E. R., . 2012. Evaluation of multi-well microelectrode arrays for neurotoxicity screening using a chemical training set. Neurotoxicology. 33, 1048–57.22652317
Meyer, D. A., . 2008. Pyrethroid modulation of spontaneous neuronal excitability and neurotransmission in hippocampal neurons in culture. Neurotoxicology. 29, 213–25.18243323
Mochizuki, Y., . 2016. Similarity in Neuronal Firing Regimes across Mammalian Species. J Neurosci. 36, 5736–47.27225764
Mohana Krishnan, B., Prakhya, B. M., 2016. In vitro evaluation of pyrethroid-mediated changes on neuronal burst parameters using microelectrode arrays. Neurotoxicology. 57, 270–281.27746124
Mundy, W. R., . 2015. Expanding the test set: Chemicals with potential to disrupt mammalian brain development. Neurotoxicol Teratol. 52, 25–35.26476195
Mundy, W. R., . 2010. Neuronal models for evaluation of proliferation in vitro using high content screening. Toxicology. 270, 121–30.20149836
Nishimura, Y., . 2015. Zebrafish as a systems toxicology model for developmental neurotoxicity testing. Congenit Anom (Kyoto). 55, 1–16.25109898
Nyffeler, J., . 2017. Combination of multiple neural crest migration assays to identify environmental toxicants from a proof-of-concept chemical library. Arch Toxicol. 91, 3613–3632.28477266
O’Brien, W. T., . 2011. Glycogen synthase kinase-3 is essential for β-arrestin-2 complex formation and lithium-sensitive behaviors in mice. The Journal of Clinical Investigation. 121, 3756–3762.21821916
OECD, Test No. 426: Developmental Neurotoxicity Study, OECD Guidelines for the Testing of Chemicals. In: 4, S., (Ed.). OECD Publishing, Paris, 2007.
Pancrazio, J. J., . 2014. Botulinum toxin suppression of CNS network activity in vitro. J Toxicol. 2014, 732913.24688538
Pearce, R. G., . 2017a. Evaluation and calibration of high-throughput predictions of chemical distribution to tissues. J Pharmacokinet Pharmacodyn. 44, 549–565.29032447
Pearce, R. G., . 2017b. httk: R Package for High-Throughput Toxicokinetics. J Stat Softw. 79, 1–26.30220889
Peterson, R. T., . 2008. Use of non-mammalian alternative models for neurotoxicological study. Neurotoxicology. 29, 546–55.18538410
Pugazhenthi, S., . 1996. Inhibition of a Src homology 2 domain containing protein tyrosine phosphatase by vanadate in the primary culture of hepatocytes. Arch Biochem Biophys. 335, 273–82.8914924
Reif, D. M., . 2016. High-throughput characterization of chemical-associated embryonic behavioral changes predicts teratogenic outcomes. Arch Toxicol. 90, 1459–70.26126630
Robinette, B. L., . 2011. In vitro assessment of developmental neurotoxicity: use of microelectrode arrays to measure functional changes in neuronal network ontogeny. Front Neuroeng. 4, 1.21270946
Rodier, P. M., 1995. Developing brain as a target of toxicity. Environ Health Perspect. 103 Suppl 6, 73–6.
Rolls, A., . 2007. Toll-like receptors modulate adult hippocampal neurogenesis. Nat Cell Biol. 9, 1081–8.17704767
Rotroff, D. M., . 2010. Incorporating human dosimetry and exposure into high-throughput in vitro toxicity screening. Toxicol Sci. 117, 348–58.20639261
Ruegg, U. T., Burgess, G. M., 1989. Staurosporine, K-252 and UCN-01: potent but nonspecific inhibitors of protein kinases. Trends Pharmacol Sci. 10, 218–20.2672462
Ryves, W. J., Harwood, A. J., 2001. Lithium inhibits glycogen synthase kinase-3 by competition for magnesium. Biochem Biophys Res Commun. 280, 720–5.11162580
Sachana, M., . 2019. International Regulatory and Scientific Effort for Improved Developmental Neurotoxicity Testing. Toxicol Sci. 167, 45–57.30476307
Salinas, E., Sejnowski, T. J., 2001. Correlated neuronal activity and the flow of neural information. Nat Rev Neurosci. 2, 539–50.11483997
Scelfo, B., . 2012. Application of multielectrode array (MEA) chips for the evaluation of mixtures neurotoxicity. Toxicology. 299, 172–83.22664482
Schroeder, O. H., . Spike train data analysis of substance-specific network activity: application to functional screening in preclinical development. 6th international meeting on substrate-integrated microelectrodes, July 8–11, 2008, Reutlingen, Germany, 2008.
Shafer, T. J., 2019. Application of Microelectrode Array Approaches to Neurotoxicity Testing and Screening. Adv Neurobiol. 22, 275–297.31073941
Shafer, T. J., . 2019. Evaluation of Chemical Effects on Network Formation in Cortical Neurons Grown on Microelectrode Arrays. Toxicol Sci. 169, 436–455.30816951
Shafer, T. J., . 2008. Complete inhibition of spontaneous activity in neuronal networks in vitro by deltamethrin and permethrin. Neurotoxicology. 29, 203–12.18304643
Sharma, P., . 2012. High-throughput screening in primary neurons. Methods Enzymol. 506, 331–60.22341232
Stambolic, V., . 1996. Lithium inhibits glycogen synthase kinase-3 activity and mimics wingless signalling in intact cells. Curr Biol. 6, 1664–8.8994831
Strickland, J. D., . 2018. Screening the ToxCast phase II libraries for alterations in network function using cortical neurons grown on multi-well microelectrode array (mwMEA) plates. Arch Toxicol. 92, 487–500.28766123
Toullec, D., . 1991. The bisindolylmaleimide GF 109203X is a potent and selective inhibitor of protein kinase C. J Biol Chem. 266, 15771–81.1874734
Tukker, A. M., . 2020. Towards animal-free neurotoxicity screening: Applicability of hiPSC-derived neuronal models for in vitro seizure liability assessment. ALTEX. 37, 121–135.31686111
Uhlhaas, P. J., . 2009. Neural synchrony in cortical networks: history, concept and current status. Front Integr Neurosci. 3, 17.19668703
Uhlhaas, P. J., Singer, W., 2006. Neural synchrony in brain disorders: relevance for cognitive dysfunctions and pathophysiology. Neuron. 52, 155–68.17015233
Upton, R. N., 2007. Cerebral uptake of drugs in humans. Clin Exp Pharmacol Physiol. 34, 695–701.17600543
USEPA, Health Effects Test Guidelines OCSPP 870.6300 Developmental Neurotoxicity Study. 1998a.
USEPA, U.S. Environmental Protection Agency Guidelines for neurotoxicity risk assessment. EPA/630/R-95/001F. USEPA, Washington, DC, 1998b.
USEPA, US Environmental Protection Agency Policy on a Common Mechanism of Action: The Organophosphate Pesticides. Vol. 64. Federal Register, Washington, D.C., 1999, pp. 5795–5799.
Vandenbossche, J., . 2010. Loperamide and P-glycoprotein inhibition: assessment of the clinical relevance. J Pharm Pharmacol. 62, 401–12.20604828
Walton, N. M., . 2006. Derivation and large-scale expansion of multipotent astroglial neural progenitors from adult human brain. Development. 133, 3671–81.16914491
Wambaugh, J. F., . 2018. Evaluating In Vitro-In Vivo Extrapolation of Toxicokinetics. Toxicol Sci. 163, 152–169.29385628
Wambaugh, J. F., . 2015. Toxicokinetic Triage for Environmental Chemicals. Toxicol Sci. 147, 55–67.26085347
Wetmore, B. A., 2015. Quantitative in vitro-to-in vivo extrapolation in a high-throughput environment. Toxicology. 332, 94–101.24907440
Wetmore, B. A., . 2012. Integration of dosimetry, exposure, and high-throughput screening data in chemical toxicity assessment. Toxicol Sci. 125, 157–74.21948869
Wright, L. S., . 2006. Human progenitor cells isolated from the developing cortex undergo decreased neurogenesis and eventual senescence following expansion in vitro. Exp Cell Res. 312, 2107–20.16631163
Wu, L. S., Li, J., 2018. High-Content Imaging Phenotypic Screen for Neurogenesis Using Primary Neural Progenitor Cells. Methods Mol Biol. 1787, 101–113.29736713
Zhang, G., . 2017. A New Statistical Approach to Characterize Chemical-Elicited Behavioral Effects in High-Throughput Studies Using Zebrafish. PLoS One. 12, e0169408.28099482