# Executive Summary

To supplement or replace the existing toxicity tests used to support pesticide registration, EPA’s OPP is actively engaged in numerous activities with respect to reducing laboratory animal use and implementing new approach methodologies (NAMs). NAM is a broad term referring to any non-animal technology, methodology, approach, or combination thereof that can be used to provide information on chemical hazard and risk assessment. As NAMs can provide human relevant information that may be challenging to test in whole animals, EPA’s OPP is also interested in using NAMs to reduce the reliance on default assumptions for risk assessment. In line with this, several years ago, the Office of Pesticide Programs (OPP) began collaborative work with the Office of Research and Development (ORD), academia, and industry to use the organophosphate pesticides (OPs) as a case study for the development of NAMs to inform extrapolation/uncertainty and safety factors in lieu of reliance on default factors. Two approaches related to these efforts are presented.

The first approach presents work completed by ORD towards developing a battery of NAMs for fit-for-purpose evaluation of developmental neurotoxicity (DNT), using OPs as a case study. This includes a microelectrode array network formation assay (MEA NFA) and high-content imaging (HCI) assays of neural cells to understand key processes relevant to neurodevelopment. These assays were found to be robust and reproducible for fit-for-purpose application to identify putative DNT-related bioactivity, with reasonable assay performance controls established. The testing results for 27 OPs found differential activity in the MEA NFA and HCI assay suite indicating a difference in DNT potential across individual chemicals.

Common to all OPs is the ability to inhibit the AChE enzyme, which prevents the breakdown of acetylcholine leading to neurotoxicity. AChE inhibition is the basis of current OP human health risk assessments. In order to compare the relative sensitivity of the MEA NFA and HCI assay results to doses that inhibit AChE in laboratory animals, in vitro to in vivo extrapolation (IVIVE) approaches using high-throughput toxicokinetic (HTTK) models were utilized to approximate NAM-derived administered equivalent doses (AEDs). These comparisons demonstrated that NAM-derived AEDs were greater than or in some cases approximated doses that inhibit AChE; however, additional information is still needed for to make conclusions regarding the relative sensitivity of individual chemicals.

The IVIVE approach used for these comparisons is driven by the chemical-specific data that are available. Due to the lack of rat clearance data for many of the OPs tested, the use of human data in the rat model was evaluated. Predictions were not found to be uniformly higher or lower when using human rather than rat data. Therefore, for chemicals that are lacking rat clearance data and have AEDs approximating the BMD/BMDL values, it is unknown whether the predictions are over- or underestimates. Pending the recommendations from the SAP and the overall weight of evidence evaluation of DNT potential based on the currently available data, the OPP may determine that rat in vitro clearance data for particular OPs are needed to better characterize these comparisons and OPP may reach out to registrants in the future to generate these data.

The MEA NFA and HCI assay suite evaluates the majority of the critical processes of neurodevelopment, including neural network formation and function, cell proliferation, apoptosis, neurite outgrowth, and synaptogenesis, and represents a significant advancement toward developing a NAM battery for fit-for-purpose DNT evaluation. Additional assays are currently under development by researchers funded by the European Food Safety Authority (EFSA) that evaluate processes not covered by the MEA NFA and HCI assays, such as migration and differentiation. The relative contribution of these assays for a fit-for-purpose NAM battery will be considered once data are available. Additionally, any OP data from these assays may be considered in the future in combination with the results of the MEA NFA and HCI assays as part of an overall weight of evidence evaluation of the DNT potential for individual OPs. Given the gaps in rat clearance data and additional DNT NAMs under development, EPA cannot make any conclusions about the impact of these approaches on the OP human health risk assessments at this time.

The second approach presents in vitro data generated by academia on behalf of pesticide registrants to calculate pharmacodynamic data derived extrapolation factors (DDEFs) for 16 OPs in accordance with the EPA’s 2014 guidance on DDEFs. EPA is soliciting comment from the SAP on the study design and methods utilized to generate the in vitro data, statistical analyses employed to calculate DDEFs, and analyses performed for a small subset of OPs to evaluate contributions of experimental and intrinsic variability. For both interspecies and intraspecies DDEFs, there were no statistical issues identified for 9 chemicals. EPA’s preliminary proposal is to use the DDEFs calculated for these 9 chemicals (bensulide oxon, chlorethoxyfos, DDVP, ethoprop, fenamiphos, methamidophos, phorate oxon sulfoxide, phosmet oxon, and terbufos oxon sulfone) in lieu of the default pharmacodynamic uncertainty factors, pending review by the SAP. For the remaining chemicals, SAP recommendations regarding warning statements and model fit issues will be considered before determining the potential use of the calculated DDEFs. Ultimately, the selection and application of DDEFs for each chemical is a policy decision that will be made by EPA.