# 4.0 Summary & Next Steps

The EPA’s OPP is actively engaged in numerous activities related to developing and implementing NAMs, which reduce reliance on laboratory animal studies and have the ability to provide human relevant information that may challenging to obtain from in vivo studies. This Issue Paper presented two approaches related to these efforts. The first approach presented work completed by ORD thus far to develop a battery of NAMs for evaluating DNT, using OPs as a case study. The MEA NFA and HCI assays were found to be robust and reproducible for fit-for-purpose application to identify putative DNT-related bioactivity, with reasonable assay performance controls established. Differential activity was observed across the 27 OPs tested in the MEA NFA and HCI assay suite. These assays evaluate the majority of the critical processes of neurodevelopment (as presented in Table 3 and Figure 2) and represent a significant advancement toward developing a NAM battery for fit-for-purpose DNT evaluation.

IVIVE approaches with HTTK models were utilized to approximate NAM-derived AEDs, which were greater than or in some cases approximating BMD/BMDL values based on AChE inhibition. Predictions from PBPK-PD models were found to be higher than HTTK predictions; however, these comparisons were limited to the 3 chemicals where PBPK-PD models could be applied. The IVIVE approach used is driven by the chemical-specific data available. Due to the lack of rat clearance data for many of the OPs tested, the use of human data in the rat model (i.e., huRat) was evaluated. Predictions were not found to be uniformly higher or lower when using human rather than rat data. Therefore, for chemicals that are lacking rat clearance data and have huRat AEDs approximating the BMD/BMDL values, it is unknown whether the predictions are over- or underestimates. Pending the recommendations from the SAP and the overall weight of evidence evaluation of DNT potential based on the currently available data, the OPP may determine that the rat in vitro clearance data for particular OPs are needed to improve AED vs. BMD/BMDL comparisons and may reach out to registrants in the future to generate these data.

Additional assays are currently under development by EFSA-funded researchers that evaluate processes not covered by the MEA NFA and HCI assays (i.e., migration and differentiation). The relative contribution of these assays for a fit-for-purpose NAM battery will be considered once data are available. Additionally, any OP data from these assays will be considered in combination with the results of the MEA NFA and HCI assays as part of an overall weight of evidence evaluation of the DNT potential for individual OPs.

The second approach presented in vitro data generated by academia on behalf of pesticide registrants to calculate pharmacodynamic DDEF values for 16 OPs in accordance with the EPA’s 2014 guidance on DDEFs. For both interspecies and intraspecies DDEFs, there were no statistical issues identified for 9 chemicals. EPA’s preliminary proposal is to use the DDEFs calculated for these 9 chemicals (bensulide oxon, chlorethoxyfos, DDVP, ethoprop, fenamiphos, methamidophos, phorate oxon sulfoxide, phosmet oxon, and terbufos oxon sulfone) in lieu of the default pharmacodynamic uncertainty factors, pending review by the SAP. For the remaining chemicals, SAP recommendations regarding warning statements and model fit issues will be considered before determining the potential use of the calculated DDEFs. Ultimately, the selection and application of DDEFs for each chemical is a policy decision that will be made by EPA.