# 3.0 Development of DDEFs for Interspecies and Intraspecies Extrapolation

## 3.1 Background

For risk assessment, default uncertainty factors are commonly applied to extrapolate toxicity data derived from animal models to humans (interspecies or UF_A_) and to account for human variability (intraspecies or UF_H_). For OP human health risk assessments, except chlorpyrifos, the default 10X interspecies and 10X intraspecies extrapolation factors have been applied. For chlorpyrifos, the PBPK-PD model is used to derive PODs. Since the model accounts for the pharmacokinetic and pharmacodynamic differences between animals and humans, the default interspecies factor was reduced to 1X for chlorpyrifos human health risk assessments. Similar PBPK-PD models have been developed for dimethoate and malathion and their oxons; these models are under review by EPA for their potential use in future risk assessments.

The EPA’s 2014 Guidance for Applying Quantitative Data to Develop DDEF for Interspecies and Intraspecies Extrapolation^11^ provides guidance on the process for identifying reliable data that are useful for quantifying interspecies and intraspecies differences to serve as the basis for empirically deriving DDEFs. When using DDEFs, interspecies and intraspecies extrapolation factors are divided into two components representing toxicokinetic (TK) variability and toxicodynamic (TD) variability. Therefore, four DDEFs can be calculated given sufficient information. Two extrapolation factors for interspecies extrapolation are: 1) extrapolation factor covering interspecies toxicokinetics (EF_AK_) to account for TK variability and 2) extrapolation factor for interspecies toxicodynamics (EF_AD_) to account for TD variability. Similarly, the two extrapolation factors for intraspecies extrapolation are: 1) extrapolation factor covering intraspecies toxicokinetics (EF_HK_) to account for TK variability; and 2) extrapolation factor for intraspecies toxicodynamics (EF_HD_) to account for TD variability. The composite factor (CF) is calculated after the appropriate DDEF values for interspecies and intraspecies differences in TK and TD have been derived as shown in Equation 3.

C F = E F_A K_ × E F_A D_ × E F_H K_ × E F_H D_ Equation 3

The CF calculation is analogous to calculating composite uncertainty factors when using the 10X defaults for UF_A_ and UF_H_. If data are only available to develop a DDEF for one component of extrapolation or another, the remaining extrapolation is done by an appropriate default procedure.

As described in the EPA’s DDEF guidance, information on MOA, even when a complete understanding of mechanism is not available, is important for DDEF derivation since DDEFs are considered in the context of toxicity endpoints most relevant for risk assessment purposes. As discussed in Section 2.2, EPA has determined that the OPs share a common mechanism of toxicity based on their shared ability to inhibit AChE.

In 2016, three OP pesticide registrants (AMVAC, FMC, and Gowan) worked in conjunction with their consultant (Exponent) and Dr. Janice Chambers from Mississippi State University to develop an experimental plan to determine if differences exist in AChE inhibition between rats and humans and estimate intra-human variability and these differences. Representatives of OPP and ORD considered the plan and supported continued development of these efforts to generate data to inform the TD variability in the DDEF development. Since 2016, there have been numerous meetings with EPA to discuss the experimental plan, data review, and statistical analyses. EPA provided feedback on experimental protocols to determine the AChE inhibition kinetic constants of OP compounds to inform interspecies and intraspecies pharmacodynamic differences. Three study reports were submitted testing 17 OP pesticides and oxons:

- MRID 50773501: malaoxon (the active metabolite of malathion) and omethoate (the active metabolite of dimethoate)
- MRID 50773502: DDVP, naled, dicrotophos, tribufos, phorate oxon sulfone (phorate metabolite), phorate oxon sulfoxide (phorate metabolite), ethoprop, methamidophos, fenamiphos, terbufos oxon sulfone (terbufos metabolite), terbufos oxon sulfoxide (terbufos metabolite), chlorethoxyfos oxon (chlorethoxyfos metabolite), and tebupirimphos oxon (tebupirimphos metabolite)
- MRID 50773503: bensulide oxon (the active metabolite of bensulide) and phosmet oxon (the active metabolite of phosmet).

A separate report was submitted on using these data to calculate pharmacodynamic DDEFs (MRID 50773504). This report includes an evaluation by Exponent of the criteria outlined in the EPA’s DDEF guidance for using in vitro data for estimating DDEFs^12^, which includes:

- Was the toxicologically active form of the agent studied?
- How directly was the measured response linked to the adverse effect?
- Are the biological samples used in the assays derived from equivalent organs, tissues, cell types, age, stage of development, and sex of the animals/humans in which the target organ toxicity was identified?
- What is the range of variability (e.g., diverse human populations and life stages) that the biological materials cover?
- If the effect occurs or can be measured in several tissues, is the studied tissue or tissue preparation an appropriate surrogate? Or, in situations where the effect is not localized, is the effect consistent across tissues?
- Does the design of the study allow for statistically valid comparisons based on such factors as replicate and sample size?
- Was chemical uptake considered when the chemical was applied to the samples so as to give comparable intracellular concentrations across tissues?
- Were similar tissues or samples evaluated across species?
- Do the concentrations in the in vitro studies allow for comparison with in vivo conditions?

EPA believes all of the criteria have been appropriately considered and met for use of in vitro data for estimating pharmacodynamic DDEFs for OP compounds based on the evaluation provided by Exponent; however, EPA has noted concerns with the sample size for intraspecies analyses. EPA provided feedback on the statistical analyses performed in this report, as well as supplemental statistical analyses (MRID 51182301) that were subsequently submitted to address EPA’s comments and concerns. Although statistical analyses and results are presented in earlier reports from Exponent, the SAP should focus on the statistical analyses and results presented in the supplemental analysis (MRID 51182301) for their evaluation and comment. Lastly, EPA has reviewed a supplemental whitepaper submitted by Exponent (MRID 50773504) that provides a summary of existing knowledge regarding AChE in rats and humans, including amino acid sequence alignments and 3D structures.

## 3.2 Methods

### 3.2.1 Laboratory Experiments

The methods used to measure kinetic constants (biomolecular rate constant k_i_, dissociation constant K_I_, and phosphorylation constant k_p_) for AChE inhibition are described in detail in MRIDs 50773501-50773503. Briefly, a continuous spectrophometric assay was used to determine AChE activities for 17 OPs, as well as paraoxon as the positive control. The assays were performed using “erythrocyte ghost” preparations (i.e., erythrocyte cell membranes separated from hemoglobin and other cytoplasmic constituents) that were obtained from either human or rat erythrocytes as the source of AChE. For humans, the kinetic constants were determined for 18 individual samples (9 adults, 5 juveniles, and 4 cord blood samples). Human AChE utilized in the experiments was derived from blood samples from individual healthy humans of both sexes (adults age 16-60, and juveniles age 10-13), as well as cord blood samples. Blood samples from multiple race and ethnic groups were included in the study. For rats, the kinetic constants were determined for three individual pooled samples from adult rats (Sprague Dawley [Crl:CD(SD)BR]). Each male sample (n=3) was prepared from the pooled blood of five male rats. Similarly, each female sample (n=3) was prepared from the pooled blood of five female rats.

The absorbance in each well was measured and the velocity of each reaction was calculated by determining the slope of the line from a plot of absorbance (proportional to product formed) as a function of time. The inhibition reaction was terminated by addition of the substrate acetylthiocholine. For each species and each inhibitor, all regressions and calculations were performed using either Microsoft Excel 2010 or SigmaPlot version 14 to obtain the AChE velocity remaining and apparent rate of AChE phosphorylation (k_app_) for determination of k_i_, k_p_, and K_I_. The key result from the experiments was k_i_, which is directly proportional to the rate of in vivo inhibition for a given internal dose. Since the inhibition of AChE from an internal dose is a pharmacodynamic process, it can be directly used in the estimation of DDEFs.

### 3.2.2 Statistical Approach

For each of the 16 OPs, Exponent used SAS PROC NLMIXED to fit nonlinear mixed models to k_app_ (the apparent rate of AChE phosphorylation in mol/L/min) as a function of the inhibitor concentration (Conc). These mixed models were specified to have a hyperbolic functional form (referred to as the classic Michaelis-Menten equation for describing the kinetics of enzyme-substrate reactions), where the parameter estimates correspond to the phosphorylation rate constant (A, min^−1^) and disassociation rate constant (B, mol/L):

k_a p p_ = (A ∗ C o n c)/(B + C o n c)

In turn, k_i_ was estimated as the ratio of the phosphorylation rate constant and the dissociation rate constant (A/B) parameters from nonlinear mixed model.

k_i_ = B i m o l e c u l a r R a t e C o n s t a n t ( L / m o l / m i n ) = k_p_ / K_I_

As part of the nonlinear mixed-effects model approach where k_app_ was nonlinearly regressed on inhibition concentration (Conc), each sample^13^ was treated as a unique experimental subject, such that each sample was allowed to have a different hyperbolic curve (i.e., each sample had a different random value of A and different random value of B). Additionally, in the nonlinear mixed-effects models, each group (e.g., species, sex, age, or ethnicity groups) is allowed to have different average A value and average B value (i.e., each group has a fixed effect A_m_ value and fixed effect B_m_ value). These fixed effect values are the average of all random A values or the average of all random B values within each group. Thus, each group is allowed to have an “average” hyperbolic curve.

k_a p p . m i t_ = ((A_m_ + γ_m i_) × C o n c_t_)/((B_m_ + φ_m i_) + C o n c_t_) + ε_m i t_

- Where k_app.mit_ is the k_app_ value of the sample i^th^ in the group m at the inhibition concentration Conc_t_,
  A_m_ and B_m_ are the fixed effects A and B of group m,
  γ_mi_ and φ_mi_ are the random effects associated with A_m_ and B_m_ of the sample i^th^ in the group m,
  γ_mi_ and φ_mi_ follow normal distributions with mean = 0 and
  variance-covariance matrix = [G_A m_ G_A B m_ G_A B m_ G_B m_] , and
- ε_mit_ is the error of the measurement of the sample i^th^ in the group m at the inhibition concentration Conc_t_, with ε_mit_~N(0, σ^2^).

The above equation can be rewritten and implemented in SAS as:

k_a p p . m i t_ = ({(A_1_ + γ_1 i_) × I [m = 1] + (A_2_ + γ_2 i_) × I [m = 2]} × C o n c_t_)/({(B_1_ + φ_1 i_) × I [m = 1] + (B_2_ + φ_2 i_) × I [m = 2]} + C o n c_t_) + ε_m i t_

- where, A_1_ and B_1_ are the fixed effects A and B of group m=1,
  A_2_ and B_2_ are the fixed effects A and B of group m=2,
  I [ m = 1 ] = {1 i f m = 1 0 i f m = 2 , and
  I [ m = 2 ] = {1 i f m = 2 0 i f m = 1

and the variance-covariance matrix of random effects γ_1i_, φ_1i_, γ_2i_ and φ_2i_ is

variance-covariance matrix = [G_A 1_ G_A B 1_ 0 0 G_A B 1_ G_B 1_ 0 0 0 0 G_A 2_ G_A B 2_ 0 0 G_A B 2_ G_B 2_]

As shown in the variance-covariance matrix above, the random effects are independent between the groups m=1 and m=2.

For each chemical, the ratio of k_i_ values between two groups (e.g., m=1 for human and m=2 for rat) was estimated using the estimated values of the parameters in the model as (A_1_ / B_1_)/(A_2_ / B_2_) , and the 95% confidence interval (CI) of the estimated ratio was calculated based on the standard error that was approximately computed using the delta method^14^ (all of these computations were done with the ESTIMATE statement in SAS PROC NLMIXED). When the ratios of the k_i_ values are from the human and rat groups, the chemical-specific ratios and their corresponding 95% CIs are used to evaluate the interspecies differences in AChE phosphorylation between two species. When the ratios of the k_i_ values are from the various human subpopulation groups (i.e., males and females; adults and infants; or Caucasian and non-Caucasian), the chemical-specific ratios and their corresponding 95% CIs are used to evaluate the intraspecies differences in AChE phosphorylation between the human subpopulations.

For each data analysis, there were two final models: one assumed that both groups (e.g., human and rat species) had the same variance-covariance matrix for random effects γ_mi_ and φ_mi_ (model 2 in SAS code) and one assumed that both groups (e.g., human and rat) had different variance covariance matrices (model 3 in SAS code)^15^. Exponent selected the results of the final model that had the lower Akaike’s Information Criterion (AIC) value. However, if the model with the lower AIC value had a SAS warning statement, but the alternative final model did not have a warning statement, Exponent selected the alternative model. In some cases, both models 2 and 3 had SAS warning statements (i.e., model fit issue), indicating the results of the selected final model should be interpreted with caution.

Exponent also conducted regression diagnostics for the selected final models of all data analyses. Based on a visual evaluation of diagnostic plots, some of the selected final models had severe outliers or a severe imbalance in the distribution of residuals in the residuals vs. predicted values plots (i.e., model fit is questionable). The results of the estimated ratios from these analyses should similarly be interpreted with caution.

For each chemical, phosphorylation rate constant (A) and disassociation rate constant (B) values of the human blood samples were calculated using the sample random value coefficients obtained from the selected final models for the human vs. rat analyses. The bimolecular rate constant of inhibition (k_i_) was then calculated as the ratio of these rate constants (A/B). Exponent then provided normal Q-Q plots of the k_i_ values and the ln(k_i_) values to support rationale for assuming the k_i_ values were lognormally distributed for all chemicals. Coverage ratios (i.e., 90%-tile/GM, 95%-tile/GM, 97.5%-tile/GM, and 99%-tile/GM) were then calculated based on the assumption that k_i_ values are lognormally distributed. These chemical-specific coverage ratios were calculated only for the final selected models with the human and rat groups and were used to evaluate the variability AChE phosphorylation within humans (i.e., intraspecies variability of AChE phosphorylation).

## 3.3 Results

The sections below provide the summary results for the interspecies data (rat to human) and the intraspecies (within human) analyses. Values are reported for 16 of the 17 OPs tested because tribufos did not produce any AChE inhibition even at a final concentration of 1 mM; therefore, k_i_ values are not reported for tribufos.

### 3.3.1 Interspecies data analyses

- There were 9 (of 16) chemicals for which we can interpret the results of estimated k_i_ ratios human/rat without any concern for severe outliers or model fit issues in the selected final models (Table 15). For all these 9 chemicals, both the 95% upper confidence limit (UCL) and lower confidence limit (LCL) for the ratios between the human estimated k_i_ values and the rat estimated k_i_ values are less than 3-fold from the point estimate (i.e., UCL < 3 and LCL > 0.33).
- As shown in Table 15, there were 6 (of 16) chemicals for which the estimated ratios of human/rat should be interpreted with caution due to severe outlier/model fit concern. Except for naled with estimated k_i_ ratio human/rat = 0.5 (95% CI = 0.35-0.66) and omethoate with estimated k_i_ ratio human/rat = 0.26 (95% CI = 0.09-0.43), the other 4 chemicals had similar k_i_ values between human and rat, and both the 95% UCL and LCL for the ratios between the human estimated k_i_ values and the rat estimated k_i_ values differ less than 2-fold (i.e., UCL < 2 and LCL > 0.5).
- There was 1 (of 16) chemical for which there was a SAS warning statement (model fit issue) in the selected final model (Table 15). The result of estimated k_i_ ratio human/rat from this model should be interpreted with caution.

Table 15 Interspecies biomolecular rate constant (k_i_) ratios and associated 95% confidence intervals for 16 OPs

Chemical | Estimated k_i_ ratio human/rat | 95% CI | | Severe outliers/model fit concern? | Warning statement/model fit issue
Chemical | Estimated k_i_ ratio human/rat | Lower | Upper | Severe outliers/model fit concern? | Warning statement/model fit issue
Bensulide oxon | 0.62^*^ | 0.42 | 0.81 | No | No
Chlorethoxyfos | 0.48^*^ | 0.39 | 0.57 | No | No
DDVP | 1.14 | 0.98 | 1.29 | No | No
Ethoprop | 2.06^*^ | 1.45 | 2.67 | No | No
Fenamiphos | 0.89 | 0.63 | 1.15 | No | No
Methamidophos | 0.86 | 0.64 | 1.09 | No | No
Phorate oxon sulfoxide | 0.84^*^ | 0.72 | 0.96 | No | No
Phosmet oxon | 1.07 | 0.83 | 1.3 | No | No
Terbufos oxon sulfone | 1.2 | 0.89 | 1.52 | No | No
Terbufos oxon sulfoxide | 1.35 | 1.2 | 1.5 | No | Yes
Dicrotophos | 0.76^*^ | 0.62 | 0.9 | Yes | No
Malaoxon | 0.96 | 0.53 | 1.39 | Yes | No
Naled | 0.50^*^ | 0.35 | 0.66 | Yes | No
Omethoate | 0.26^*^ | 0.09 | 0.43 | Yes | No
Phorate oxon sulfone | 0.88 | 0.5 | 1.25 | Yes | No
Tebuprimphos oxon | 0.44^*^ | 0.21 | 0.67 | Yes | No

* Statistically significantly different from 1 (p<0.05)

### 3.3.2 Intraspecies data analyses

Three stratified intraspecies data analyses were separately conducted for each of 16 chemicals. These analyses are presented on pages 23-30 of MRID 51182301. However, there is low confidence in the results of these analyses, in part, due to the small sample sizes following stratification. EPA is concerned that results based on a limited number of samples would not be representative of the subpopulations being evaluated. There were 14 adult samples and 4 infant samples in the analysis of [underlined: adult] vs. [underlined: infant] (number of samples per group would be very small if the sample was further split into additional age groups). There were 8 [underlined: male] samples and 10 [underlined: female] samples in the analysis of male vs. female. There were 13 [underlined: Caucasian] samples and 5 [underlined: non-Caucasian] samples^16^ in the analysis of Caucasian vs. non-Caucasian. Additionally, several of the models for these analyses resulted in model outliers or had model convergence issues. Further exploratory analysis would be needed to address these model fit issues, which may in part be due to the limited number of samples.

Exponent estimated the coverage ratios of k_i_ distributions (Table 16), where the k_i_ values were estimated from the nonlinear mixed effects models using all available human samples. The human fixed effects and sample random of Phosphorylation Constant k_p_ (SAS coding as HA and RHA, respectively) and Dissociation Constant K_I_ (SAS coding as HB and RHB, respectively) obtained from the selected final models of human vs. rat analyses were used to calculate the k_i_ values (k_i_ = (HA + RHA)/(HB+RHB)). The coverage ratios of the k_i_ distributions, that is, the ratio between various upper percentiles values and the geometric mean or GM (e.g., 90%-tile/GM, 95%-tile/GM, 97.5%-tile/GM, and 99%-tile/GM) were calculated based on the assumption that the k_i_ values were distributed lognormally. Among 9 chemicals with no issue or concern of model fit, all the k_i_ ratios of the 95%-tile/GM were less than 3. Of those 7 chemicals with model fit issues or model fit concerns in the analysis of human vs. rat, 2 chemicals (malaoxon and naled) had estimated k_i_ ratios of the 95%-tile/GM > 3.

Exponent also presented the results of an alternative coverage ratio analysis in MRID 51182301, which was based on fitting separate nonlinear models to each of the samples. For each chemical, the estimated nonlinear model for each human subject was considered completely independent and the model parameters were estimated completely independent of one another. However, EPA prefers the other mixed effect model approach over this alternative analysis because it better reflects the structure of the observed data and leverages the information contained in the entire set of chemical-specific data.

Table 16 Intraspecies coverage ratios of biomolecular rate constant (k_i_) distributions for 16 OPs assuming lognormal distribution

Model fit issue/ model fit concern | Chemical | GM | GSD | 90%-tile/GM | 95%-tile/GM | 97.5%-tile/GM | 99%-tile/GM
No | Bensulide oxon | 3.7E+02 | 1.30 | 1.40 | 1.54 | 1.67 | 1.84
No | Chlorethoxyfos | 2.5E+07 | 1.17 | 1.23 | 1.30 | 1.37 | 1.45
No | DDVP | 5.1E+04 | 1.18 | 1.24 | 1.31 | 1.38 | 1.47
No | Ethoprop | 1.5E+03 | 1.18 | 1.24 | 1.32 | 1.39 | 1.48
No | Fenamiphos | 1.5E+02 | 1.23 | 1.31 | 1.41 | 1.50 | 1.62
No | Methamidophos | 1.1E+03 | 1.23 | 1.31 | 1.41 | 1.51 | 1.63
No | Phorate oxon sulfoxide | 5.2E+04 | 1.12 | 1.15 | 1.20 | 1.24 | 1.29
No | Phosmet oxon | 1.0E+05 | 1.21 | 1.27 | 1.36 | 1.45 | 1.55
No | Terbufos oxon sulfone | 3.8E+05 | 1.56 | 1.77 | 2.08 | 2.39 | 2.82
Model fit concern | Dicrotophos | 5.3E+03 | 1.22 | 1.29 | 1.38 | 1.47 | 1.58
Model fit concern | Malaoxon | 1.1E+05 | 2.49 | 3.22 | 4.48 | 5.97 | 8.33
Model fit concern | Naled | 3.1E+06 | 2.16 | 2.69 | 3.56 | 4.54 | 6.02
Model fit concern | Omethoate | 6.6E+02 | 1.71 | 1.99 | 2.41 | 2.86 | 3.48
Model fit concern | Phorate oxon sulfone | 7.7E+04 | 1.39 | 1.53 | 1.72 | 1.91 | 2.16
Model fit concern | Tebupirimphos oxon | 6.6E+05 | 1.73 | 2.02 | 2.47 | 2.94 | 3.59
Model fit issue | Terbufos oxon sulfoxide | 1.1E+04 | 1.32 | 1.43 | 1.58 | 1.72 | 1.91

GM = geometric mean; GSD = geometric standard deviation

Exponent also conducted another data analysis to evaluate the variation of k_i_ between human samples (Table 17). The k_i_ data of 3 chemicals (naled, omethoate, and phosmet oxon) from 3 subsamples from each of 4 human samples were available. Note that these k_i_ values were obtained from the nonlinear regression analyses that Exponent separately performed on each subsample data. To achieve the normality assumption, log-transformation was applied to the k_i_ data, then a mixed-effects model (SAS PROC MIXED) with human sample ID as random effect (i.e., experimental subject in the model) was used to analyze the log-transformed k_i_ data of each chemical. The intraclass correlation (ICC), between subject variance (this is actually the estimate of the variance of human log(k_i_), and within subject variance (this is actually the variance of log(experimental error)) were obtained from the model. Using the estimated variance of human log(k_i_) obtained from the mixed-effect model, the coverage ratios of the k_i_ distributions^17^ were calculated for each chemical and are presented in the following table.

As described in MRID 51182301, the results from this analysis are not consistent across the 3 chemicals. For naled, there was relatively large within subject variability with 84% of the total variability due to differences observed between the 3 replicate analyses of the human blood samples. Whereas, for phosmet oxon, only 3% of the total variability was due to differences in the 3 replicate analyses of the blood sample; 97% of the observed variability was due to the differences between human subjects.

Table 17 Coverage ratios of biomolecular rate constant (k_i_) distributions calculated using subsample data assuming lognormal distribution

Chemical | GM | GSD_total_ | ICC | GSD^a^_between human_ | 90%-tile/GM | 95%-tile/GM | 97.5-%tile/GM | 99%-tile/GM
Naled | 2.7E+06 | 2.1 | 0.84 | 1.86 | 2.4 | 3.0 | 3.7 | 4.8
Omethoate | 6.9E+02 | 2.2 | 0.20 | 1.17 | 1.6 | 1.8 | 2.0 | 2.3
Phosmet Oxon | 9.8E+04 | 1.3 | 0.027 | 1.01 | 1.1 | 1.1 | 1.1 | 1.1

a GSD_between human_ is the geometric standard deviation of between human sample variation, calculated based on the formula ICC = between human sample variance/Total Variance = between human sample variance/(between human sample variance + variance of experimental errors). Specifically, GSD _between human_ = exp(sqrt([ln(GSD_total_) * ln(GSD_total_)]*ICC)).

## 3.4 Proposed Approach to the Human Health Risk Assessment

### 3.4.1 Interspecies Pharmacodynamic DDEFs

The interspecies pharmacodynamic DDEFs ranged from 0.26 to 2.06. All DDEFs, except one value (ethoprop), were approximately 1 or less. There were no concerns for warning statements, severe outliers, and/or model fit issues for 9 of the chemicals tested. These included bensulide oxon, chlorethoxyfos, DDVP, ethoprop, fenamiphos, methamidophos, phorate oxon sulfoxide, phosmet oxon, and terbufos oxon sulfone. EPA’s prelimary proposal is to use the pharmacodynamic DDEFs presented in Table 15 for these 9 chemicals in lieu of the 3X default interspecies pharmacodynamic uncertainty factor for human health risk assessment, pending review by the SAP. Although some values are less than 1, the EPA’s DDEF guidance states that interspecies pharmacodynamic values “can be less than 1 if the data show humans are less sensitive than test species” but the decision of what value to use is considered policy and beyond the scope of the SAP.

For the remaining chemicals, there are concerns with using the DDEFs due to warning statements, potential outliers, and/or model fit issues. The OPP is soliciting feedback and advice from the SAP on the warning statements and model fit issues as part of Charge Question 6.

### 3.4.2 Intraspecies Pharmacodynamic DDEFs

Due to small sample sizes, the Agency does not have confidence in the stratified analyses (adult/infant, male/female, and Caucasian/non-Caucasian). There is more confidence in the coverage ratios (the ratio between various upper percentiles values and the geometric mean) that were calculated using all of the available human samples; however, it is still questionable whether the sample size (n=18) is sufficient and representative for these analyses. The same 9 chemicals listed in Section 3.4.1 for interspecies extrapolation with no concerns for warning statements, severe outliers, and/or model fit issues were also found to have no concerns for intraspecies pharmacodynamic DDEFs. Therefore, EPA’s preliminary proposal is to use the intraspecies pharmacodynamic DDEFs generated for bensulide oxon, chlorethoxyfos, DDVP, ethoprop, fenamiphos, methamidophos, phorate oxon sulfoxide, phosmet oxon, and terbufos oxon sulfone (Table 16) in lieu of the 3X default intraspecies pharmacodynamic uncertainty factor, pending review by the SAP. The percentile used is a policy decision that will be made by the OPP when applying these data for human health risk assessments and beyond the scope of the SAP.

For the remaining chemicals, there are concerns with using the DDEFs due to warning statements, potential outliers, and/or model fit issues. The OPP is soliciting feedback and advice from the SAP on the warning statements and model fit issues as part of Charge Question 6. Additionally, in Charge Question 8, EPA is seeking advice from the SAP on the utility of the analyses performed for a subset of OPs to evaluate experimental and intrinsic variability and whether additional data should be generated for other OPs.

11 https://www.epa.gov/risk/guidance-applying-quantitative-data-develop-data-derived-extrapolation-factors-interspecies-and

12 These criteria can be found in Section 2.4 on page 19 of the EPA’s 2014 Guidance for Applying Quantitative Data to Develop DDEFs for Interspecies and Intraspecies Extrapolation.

13 The term “sample” refers to blood samples either collected from an individual human subject or pooled together from a group of rats.

14 Billingsley, P. (1986). Probability and Measure. 2nd ed. New York: John Wiley & Sons.

15 The same variance-covariance matrix model (model 2) assumes that the variations of random effects and the correlation between the random effects of the samples are the same or similar between human samples and animal samples. A different variance-covariance matrix model (model 3) assume the variation of random effects and the correlation between random effects of samples are different between human samples and rat samples.

16 The Exponent analysis and nomenclature included African American (n=3) and Hispanic subjects (n=2) in the “non-Caucasian” category for this analysis.

17 The ratio between various upper percentiles values and the geometric mean or GM (e.g., 90%-tile/GM, 95%-tile/GM, 97.5%-tile/GM, and 99%-tile/GM)