# 1.0 Introduction

In 2007, the National Research Council’s report on Toxicity Testing in 21^st^ Century: A Vision and a Strategy was published which encouraged a new paradigm in testing that reduces the reliance on using laboratory animals while moving towards in vitro and in silico predictive approaches that are more efficient and human relevant. EPA’s Office of Pesticide Programs (OPP) has developed a strategic vision for implementing the 2007 NRC report on Toxicity Testing in the 21st Century. This strategic vision has multiple components involving a combination of computational and predictive modeling approaches, in vitro techniques, and limited, targeted in vivo testing. To supplement or replace the existing toxicity tests used to support pesticide registration, EPA’s OPP is actively engaged in numerous activities with respect to reducing laboratory animal use and implementing in vitro and computational approaches. Development and implementation of non-animal testing has been supported by the EPA, with the EPA Administrator signing a directive in 2019 that prioritizes efforts to reduce animal testing and a goal to reduce requests for and funding of mammalian studies by 30% by 2025. As new approach methodologies (NAMs) can provide human relevant information that may be challenging to test in whole animals, EPA’s OPP is also interested in using NAMs to reduce the reliance on default assumptions for risk assessment, including the application of 10X default uncertainty factors each for interspecies and intraspecies extrapolations.

In line with this, several years ago, OPP began collaborative work with EPA’s Office of Research and Development (ORD), academia, and industry to use the organophosphate pesticides (OPs), as a case study, for the development of NAMs for purposes of using NAM data to inform extrapolation/uncertainty and safety factors in lieu of reliance on default factors. This research is at a point where external peer review and public comment would be useful to specifically inform human health risk assessment for the OP class of insecticides and also as part of confidence building activities needed to implement NAMs in human health risk assessment more broadly. If appropriate, EPA’s OPP may use such NAM information as part of a weight of evidence evaluation for the 10X Food Quality Protection Act (FQPA) Safety Factor. Additionally, in vitro acetylcholinesterase (AChE) inhibition data has been generated for OP compounds. The OPP is considering the potential use of these data to develop interspecies and/or intraspecies data-derived extrapolation factors (DDEFs) in accordance with EPA’s 2014 Guidance for Applying Quantitative Data to Develop DDEFs for Interspecies and Intraspecies Extrapolation^1^.

## 1.1 Regulatory Context

Pesticides are regulated in the United States under both the Federal Insecticide, Fungicide, and Rodenticide Act (FIFRA) and the Federal Food, Drug and Cosmetics Act (FFDCA), which were both amended in 1996 by the Food Quality Protection Act. Under FIFRA, EPA reviews each registered pesticide at least every 15 years to determine whether it continues to meet the standard for registration. The current 15-year cycle for Registration Review of OPs is due for completion by October 1, 2022. OPs are a class of insecticides with numerous uses including application in agriculture on many crops and by public health organizations for mosquito control. Twenty-two OPs are undergoing Registration Review. Under the FQPA, EPA must consider aggregate risk from exposure to a pesticide from multiple sources (food, water, residential and other non-occupational sources) and consider cumulative exposure to pesticides that have common mechanisms of toxicity. In addition, as part of FQPA, EPA must consider potential for susceptibility of children to pesticides.

Common to all OPs is the ability to inhibit the AChE enzyme, which prevents the breakdown of acetylcholine leading to neurotoxicity. EPA conducts human health risk assessments for each individual OP in aggregate assessments in addition to the class of OPs in the cumulative risk assessment. OPP has historically used 10% AChE inhibition in red blood cells (RBCs) or brain as the biological response for human health risk assessment. In the early 2000s, scientific evidence from epidemiology, laboratory animals, and mechanistic studies began to emerge that OPs, particularly chlorpyrifos, may adversely affect brain development. Developmental neurotoxicity (DNT) studies are used to evaluate the developing nervous system and are conditionally required under the 40 CFR Part 158 toxicology data requirements for pesticides^2^. EPA issued data call-ins for in vivo DNT studies for OPs; however, none of the 18 submitted DNT studies for OPs were found to be more sensitive than AChE inhibition and were not used to derive points of departure (PODs) for human health risk assessment. OPP has spent more than 10 years evaluating the scientific evidence regarding the potential impact of OP exposure on neurodevelopment, including convening multiple Scientific Advisory Panel (SAP) meetings (2008, 2012, 2016). The SAP reports have provided numerous recommendations for additional research and sometimes conflicting advice for how EPA should consider (or not consider) the epidemiology data in conducting EPA’s Registration Review for human health risk assessments. The Agency is [underlined: not] soliciting comment on the epidemiological and animal behavior studies as part of this SAP. The OPs are being presented as a case study for the development of a battery of NAMs to evaluate DNT for inclusion in an overall weight of evidence evaluation.

## 1.2 Scope of the Draft Issue Paper

This draft document includes two major sections:

Section 2 begins with a description of the in vivo DNT guideline, its attributes, and uncertainties followed by a summary of experiments and statistical analyses of work done by ORD to develop a battery of NAMs for evaluating DNT. Available results for 27 OPs will be presented. This work also involves in vitro to in vivo extrapolation (IVIVE) to estimate NAM-derived administered equivalent doses (AEDs), which are compared with rat benchmark dose (BMD) and associated lower confidence bound (BMDL) values estimated from AChE inhibition data used in EPA’s risk assessments. This Issue Paper does not propose any chemical-specific or class-based FQPA Safety Factor. Moreover, EPA is [underlined: not] soliciting comment on the magnitude of the FQPA Safety Factor, as this is a policy decision that encompasses information beyond the scope of the NAM evaluation (e.g., completeness of exposure and toxicology data). EPA is soliciting comment from the SAP on the use of in vitro assays developed by ORD for evaluating neurodevelopmental endpoints and the ability of the currently available battery of assays to cover critical processes in neurodevelopment. Additionally, EPA is soliciting comment on the process taken to compare AEDs to BMD/BMDL values based on AChE inhibition in order to compare their relative sensitivity.

Section 3 provides background on the EPA’s 2014 guidance on the development of DDEFs and describes experiments conducted for the purposes of developing interspecies and intraspecies pharmacodynamic DDEFs. The experiments were performed by academia on behalf of pesticide registrants and evaluated in vitro AChE inhibition constants in rats and humans for 17 OPs, with inhibition constants generated for 16 of the 17 OPs. This section summarizes these experiments, associated statistical analyses, and provides EPA’s interpretation and recommendations for their appropriate use. EPA is soliciting comment from the SAP on the study design and methods utilized to generate the in vitro data, statistical analyses employed to calculate DDEFs, and analyses performed for a small subset of OPs to evaluate contributions of experimental and intrinsic variability.

1 https://www.epa.gov/risk/guidance-applying-quantitative-data-develop-data-derived-extrapolation-factors-interspecies-and

2 https://www.ecfr.gov/cgi-bin/text-idx?tpl=/ecfrbrowse/Title40/40cfr158_main_02.tpl