# About this Report

The Interagency Coordinating Committee on the Validation of Alternative Methods (ICCVAM) facilitates the development, validation, and regulatory acceptance of test methods that replace, reduce, or refine the use of animals in testing.

The ICCVAM Authorization Act of 2000 directed ICCVAM to prepare a progress report on its first anniversary and biennially thereafter.

In January 2018, ICCVAM published A Strategic Roadmap for Establishing New Approaches to Evaluate the Safety of Chemicals and Medical Products (https://ntp.niehs.nih.gov/go/natl-strategy) in the United States. The roadmap described how ICCVAM agencies will encourage development of new technologies for, support utilization of, and build confidence in new methods. This report summarizes progress toward these goals during 2020–2021.

The ICCVAM Biennial Report is prepared by the National Toxicology Program (NTP) Interagency Center for the Evaluation of Alternative Toxicological Methods (NICEATM), with support from the NTP Office of Policy, Review, and Outreach. The text is not copyrighted and can be reprinted without permission. If you use parts of the Biennial Report in a publication, please provide NICEATM with a copy for our records.

Send comments or suggestions to NICEATM (https://tools.niehs.nih.gov/webforms/index.cfm/main/formViewer/form_id/521/to/niceatm)

NICEATM Acting Director: Nicole Kleinstreuer

NICEATM Project Officer/Contracting Officer’s Representative: Pei-Li Yao

Report Editor: Catherine Sprankle