# About ICCVAM and NICEATM

The ICCVAM Authorization Act of 2000 (https://ntp.niehs.nih.gov/iccvam/docs/about_docs/pl106545.pdf) (42 U.S.C. 285l-3) established ICCVAM, which is supported by the National Toxicology Program Interagency Center for the Evaluation of Alternative Toxicological Methods (NICEATM). The two groups work collaboratively to evaluate new and improved testing approaches applicable to the needs of U.S. federal agencies. The articles below provide background information on NICEATM and ICCVAM.

## ICCVAM Establishment and Purpose

Tags: ICCVAM, NIEHS

U.S. regulatory agencies are charged to protect human and animal health and the environment. To do this, agencies must determine the hazards presented by substances such as pesticides, consumer products, and workplace chemicals. Testing these substances provides information about possible hazards and enables informed decisions about responsible use, storage, and disposal.

Many currently accepted test methods use laboratory animals. Alternative test methods are methods that replace animal use with non-animal test systems or lower species, reduce the number of animals required for a specific test procedure, or refine animal use to enhance animal well-being and lessen or avoid pain and distress. Collectively, the principles of replacement, reduction, or refinement of animal use for scientific research or product safety testing are referred to as the 3Rs. More recently, the term “new approach methodologies” has been adopted as a broadly descriptive reference to any technology, methodology, approach, or combination of these that can be used to provide information on chemical hazard and risk assessment and that support the 3Rs.

The ICCVAM Authorization Act of 2000 (https://ntp.niehs.nih.gov/iccvam/docs/about_docs/pl106545.pdf) (42 U.S.C. 285l-3) established the Interagency Coordinating Committee on the Validation of Alternative Methods (ICCVAM) to

“Establish, wherever feasible, guidelines, recommendations, and regulations that promote the regulatory acceptance of new or revised scientifically valid safety testing methods that protect human and animal health and the environment while reducing, refining, and replacing animal tests and ensuring human safety and product effectiveness.”

The ICCVAM Authorization Act states that the purposes of ICCVAM are to:

- Increase the efficiency and effectiveness of federal agency test method review.
- Eliminate unnecessary duplicative efforts and share experiences between federal regulatory agencies.
- Optimize utilization of scientific expertise outside the federal government.
- Ensure that new and revised test methods are validated to meet the needs of federal agencies.
- Reduce, refine, and replace the use of animals in testing, where feasible.

ICCVAM is a permanent interagency committee of NIEHS under the NTP Interagency Center for the Evaluation of Alternative Toxicological Methods (NICEATM). In October 2020, VA ORD joined ICCVAM to become the 17^th^ ICCVAM member agency.

## ICCVAM Member Agencies

Tags: ICCVAM

- Agency for Toxic Substances and Disease Registry (ATSDR)
- National Cancer Institute (NCI)
- National Institute for Occupational Safety and Health (NIOSH)
- National Institute of Environmental Health Sciences (NIEHS)
- National Institute of Standards and Technology (NIST)
- National Institutes of Health (NIH)
- National Library of Medicine (NLM)
- Occupational Safety and Health Administration (OSHA)
- U.S. Consumer Product Safety Commission (CPSC)
- U.S. Department of Agriculture (USDA)
- U.S. Department of Defense (DoD)
- U.S. Department of Energy (DOE)
- U.S. Department of the Interior (DOI)
- U.S. Department of Transportation (DOT)
- U.S. Department of Veterans Affairs Office of Research and Development (VA ORD)
- U.S. Environmental Protection Agency (EPA)
- U.S. Food and Drug Administration (FDA)

## ICCVAM Duties and Activities

Tags: ICCVAM

The ICCVAM Authorization Act (https://ntp.niehs.nih.gov/iccvam/docs/about_docs/pl106545.pdf) directs ICCVAM to carry out the following duties:

- Coordinate the technical review and evaluation of new, revised, or alternative test methods.
- Foster interagency and international harmonization of test protocols that encourage replacing, reducing, and refining animal test methods.
- Assist with and provide guidance on validation criteria and processes.
- Promote the acceptance of scientifically valid test methods.
- Promote awareness of accepted test methods.
- Submit ICCVAM test method recommendations to appropriate U.S. federal agencies.
- Consider requests from the public to review and evaluate new, revised, or alternative test methods that have evidence of scientific validity.
- Make ICCVAM’s final test recommendations available to the public.
- Prepare reports on ICCVAM progress and accomplishments under the Act and make them available to the public.

## ICCVAM Workgroups

Tags: ICCVAM, acute toxicity, ecotoxicity, IVIVE, metrics, nanomaterials

ICCVAM establishes ad hoc workgroups (https://ntp.niehs.nih.gov/go/iccvam-wg) to perform specific tasks important for the development or validation of alternatives to animal testing. The workgroups are composed of representatives from agencies that use or require data from the topic of interest.

Representatives of partner organizations in the International Cooperation on Alternative Test Methods may also be invited to participate in a workgroup.

ICCVAM workgroups play a key role in carrying out ICCVAM activities, including implementing the goals of the Strategic Roadmap for Establishing New Approaches to Evaluate the Safety of Chemicals and Medical Products in the United States (https://ntp.niehs.nih.gov/whatwestudy/niceatm/natl-strategy/index.html). When a workgroup completes its charge tasks, it transitions to an expert group to facilitate continued communication and engagement in the area of interest.

During 2020-2021, ICCVAM had active workgroups focused on the following areas:

- Acute toxicity: co-chairs Donald Cronce, Ph.D. (DoD) and Grace Patlewicz, Ph.D. (EPA)
- Consideration of alternative methods: co-chairs Jessie Carder (USDA) and Matthew Johnson, D.V.M., DACLAM (DoD)
- Ecotoxicology: co-chairs William Eckel, Ph.D. (EPA) and Natalia Garcia-Reyero Vinas, Ph.D. (DoD)
- In vitro to in vivo extrapolation: co-chairs Moiz Mumtaz, Ph.D. (ATSDR) and Cecilia Tan, Ph.D. (EPA)
- Metrics: transitioned to expert group status in April 2021; co-chairs Suzanne Fitzpatrick, Ph.D., D.A.B.T. (FDA) and Matthew Johnson, D.V.M., DACLAM (DoD)
- Nanomaterials: transitioned to expert group status in December 2021; chair Elijah Petersen, Ph.D. (NIST)
- Read across: chair Grace Patlewicz, Ph.D. (EPA)
- Validation: co-chairs Suzanne Fitzpatrick, Ph.D., D.A.B.T. (FDA), John Gordon, Ph.D. (CPSC), and Elijah Petersen, Ph.D. (NIST)

## How NICEATM Supports ICCVAM

Tags: ICCVAM, NIEHS

NICEATM, an office within the NIEHS Division of NTP (https://www.niehs.nih.gov/research/atniehs/dntp/index.cfm), provides technical and scientific support for ICCVAM and ICCVAM workgroup activities, peer review panels, expert panels, workshops, and validation efforts.

In addition to providing support for ICCVAM, NICEATM:

- Supports NTP activities, especially those contributing to the U.S. government’s interagency Tox21 initiative.
- Conducts analyses and evaluations, and coordinates independent validation studies on novel and high-priority alternative testing approaches.
- Provides information to test method developers, regulators, and regulated industry through its website and workshops on topics of interest.

### NICEATM staff

NIEHS

- Nicole Kleinstreuer, Ph.D., Acting Director
- Helena Hogberg, Ph.D., Toxicologist
- Kamel Mansouri, Ph.D., Computational Chemist
- Matthew Stout, Ph.D., Toxicologist, Project Officer
- Pei-Li Yao, Ph.D., Toxicologist

NICEATM Contract Staff (Integrated Laboratory Systems LLC, an Inotiv Company)

- David Allen, Ph.D., Principal Investigator
- Steven Morefield, M.D., Project Manager
- Jaleh Abedini, M.S.
- Todd Auman, Ph.D.
- Shannon Bell, Ph.D.
- Patricia Ceger, M.S., D.A.B.T.
- Xiaoqing Chang, Ph.D., D.A.B.T.
- Neepa Choksi, Ph.D.
- Bethany Cook, M.S.
- Amber Daniel, M.S.
- Jon Hamm, Ph.D.
- David Hines, Ph.D.
- Agnes Karmaus, Ph.D.
- Eric McAfee (subcontractor, Sciome LLC)
- Oluwakemi Oyetade, M.S.
- Jason Phillips (subcontractor, Sciome LLC)
- John Rooney, Ph.D.
- Catherine Sprankle, M.S.
- Judy Strickland, Ph.D., D.A.B.T.
- Kimberly To, Ph.D.
- James Truax, M.A.

## ICCVAM Advisory Committee

Tags: ICCVAM

The ICCVAM Authorization Act established the Scientific Advisory Committee on Alternative Toxicological Methods (SACATM) (https://ntp.niehs.nih.gov/about/org/sacatm/index.html). SACATM advises the Director of NIEHS, NICEATM, and ICCVAM about NICEATM and ICCVAM activities.

SACATM, which is directed by its charter to meet at least once each fiscal year, met in September 2020 and September 2021.

Roster of SACATM Members 2020-2021

Name | Title | Company | Appointment End Year
Antonio Baines, Ph.D. (ad hoc 2021) | Associate Professor, Department of Biological and Biomedical Sciences | North Carolina Central University, Durham, NC | N/A
Szczepan W. Baran, V.M.D., M.S. | Head of Emerging Technologies | Novartis Institute for Biomedical Research, Cambridge, MA | 2024
Ellen Berg, Ph.D. (ad hoc 2021) | Chief Scientific Officer, Translational Biology | Eurofins Discovery, Burlingame, CA | N/A
Michael B. Bolger, Ph.D. | Chief Scientist | Simulations Plus, Inc., Lancaster, CA | 2020
Joseph L. Charest, Ph.D. | Biomedical Solutions Program Manager | The Charles Stark Draper Laboratory, Inc., Cambridge, MA | 2022
Amy Clippinger, Ph.D. | Director | PETA Science Consortium International e.V., Washington, DC | 2022
Kelly P. Coleman, Ph.D., D.A.B.T., RAC | Distinguished Scientist and Technical Fellow | Medtronic PLC, Minneapolis, MN | 2020
K. Nadira De Abrew, Ph.D. (Chair) | Senior Scientist (Toxicologist) | The Procter & Gamble Company, Cincinnati, OH | 2022
Denis Fourches, Ph.D. | Computational Chemist | Oerth Bio, Raleigh, NC | 2023
Sean C. Gehen, Ph.D., D.A.B.T. | Regulatory Sciences Team Leader | Corteva Agriscience, Indianapolis, IN | 2022
Sue Leary, M.S. | President | Alternatives Research and Development Foundation, Jenkintown, PA | 2024
Adrian Nañez, Ph.D. (ad hoc 2021) | Senior Medical Science Liaison – Oncology (Heme) | Takeda, San Antonio, TX | N/A
Priyanka Sura, D.V.M., M.S., D.A.B.T. | Director Regulatory and Product Stewardship, Trade Compliance Manager | ANGUS Chemical Company, Buffalo Grove, IL | 2024
Tamara Tal, Ph.D. | Senior Scientist, Group Leader | Helmholtz Center for Environmental Research – UFZ, Leipzig, Germany | 2023
Misti Ushio, Ph.D. | Chief Executive Officer | TARA Biosystems, Inc., New York, NY | 2024
ClarLynda Williams-Devane, Ph.D. | Director, State Center for Health Statistics | North Carolina Department of Health and Human Services, Raleigh, NC | 2020