# Leadership

As an interagency committee of the U.S. federal government, ICCVAM takes a leadership role in promoting the use of NAMs. ICCVAM agencies promote new testing approaches through providing funding to support development of new methods, as well as through international interactions and collaborations.

## Resources for Alternative Methods Development

To support developers of new testing approaches, ICCVAM is drafting a new document describing criteria and processes for validation and regulatory acceptance of toxicological testing methods. During 2020 and 2021, NIEHS and other ICCVAM member agencies also supported alternative methods development through grants to small businesses and academic institutions. These grants supported development of new testing approaches for ecotoxicity and models to advance COVID-19 research. They also supported development of platforms such as iPSCs and in vitro organoids, computational approaches, and methods to incorporate genetic diversity into NAMs.

### Updated criteria and processes for validation and regulatory acceptance of toxicological test methods

Tags: ICCVAM, ATSDR, CPSC, DoD, VA ORD, EPA, FDA, NIEHS, NIST, OSHA

In 1997, ICCVAM published Validation and Regulatory Acceptance of Toxicological Test Methods (https://ntp.niehs.nih.gov/iccvam/docs/about_docs/validate.pdf), which recommended criteria and processes for validation and regulatory acceptance of toxicological testing methods that would be useful to federal agencies and the scientific community. Approaches to validating new methods have evolved considerably since the publication of this document. New concepts have emerged related to the development of NAMs and the evaluation of their utility for regulatory uses, such as the qualification of a NAM for a particular context of use (also known as fit-for-purpose). However, guidance is needed on specific processes to put these concepts into practice.

In 2021, ICCVAM established a Validation Workgroup to consider this issue. The workgroup, which has members from nine ICCVAM agencies, is applying the advances of the last two decades to a new document describing criteria and processes for validation and regulatory acceptance of toxicological testing methods. In addition to supporting development of flexible validation practices that consider context of use, the new document will address the need to align validation approaches in a manner that encourages international harmonization and incorporates best practices for quality and quality systems development. The document will draw upon recent well-established validation publications to ensure alignment of approaches.

As of December 2021, drafting of the new document was in progress, and it is envisioned that it will be made available for public comment sometime in 2022.

### Small business grants to support alternative methods development

Tags: NIEHS, Tox21, machine learning

Throughout 2020 and 2021, NIEHS provided funding for small businesses (https://www.niehs.nih.gov/research/supported/translational/sbir/index.cfm) developing technologies of interest to the Tox21 program. The funding was offered as part of the 2020 and 2021 Omnibus Solicitations of the National Institutes of Health (NIH), Centers for Disease Control, and FDA for small business grant applications to support development and commercialization of innovative technologies. Technologies supported by NIEHS included improved or expanded testing methods for toxicity screening, computational approaches for predictive toxicology, and other technologies such as alternative or improved methods for fixing and preserving tissues.

In addition to funding offered via the Omnibus Solicitations, NIEHS offers grants to support development of specific types of technologies targeting specific endpoints. Funding offered in 2020 and 2021 supported development of:

- Chemical testing resources and approaches that reflect the genetic diversity (https://grants.nih.gov/grants/guide/rfa-files/RFA-ES-20-008.html) among human populations, including panels of human or rodent cells or cell lines, lower organism strains with well-characterized genetic backgrounds, or in silico approaches to enhance the ability to characterize the effects of genetic variation in toxicity testing (December 2019, submissions open through February 2020).
- Application of artificial intelligence and machine learning (https://grants.nih.gov/grants/guide/rfa-files/RFA-ES-21-002.html) for advancing environmental health sciences (December 2020)

### Funding to develop machine learning tools

Tags: DOE, machine learning

In March 2021, DOE announced availability of $29 million in grants to develop new tools to analyze massive amounts of scientific information. The grants were intended to support development of tools that use technologies such as artificial intelligence, machine learning, and advanced algorithms. They focused on two specific areas, data-intensive scientific machine learning and analysis (https://www.grants.gov/web/grants/view-opportunity.html?oppId=332368) to help detect patterns in data, and randomized algorithms for extreme-scale science (https://www.grants.gov/web/grants/view-opportunity.html?oppId=332386) to make large data sets easier to understand.

### Grants to develop in vitro models of SARS-CoV-2 infection and treatment

Tags: FDA, NIH, COVID-19, MPS, biologics

In April 2020, NCATS issued two Notices of Special Interest to support research in collecting and examining data on the risks and outcomes for COVID-19 infections using MPS. Such work is expected to advance the translation of research findings into diagnostics, therapeutics, and vaccines. Applications for administrative supplements (https://grants.nih.gov/grants/guide/notice-files/NOT-TR-20-016.html) and competitive revisions (https://grants.nih.gov/grants/guide/notice-files/NOT-TR-20-017.html) for existing grants to advance COVID-19 research were accepted through January 2022.

In a separate effort announced in September 2020, FDA awarded over $5 million to a global collaboration to inform the development of treatments and vaccines for coronavirus infections (https://www.fda.gov/emergency-preparedness-and-response/mcm-regulatory-science/fda-and-global-partners-analyze-coronavirus-samples). The collaboration, led by the University of Liverpool (https://news.liverpool.ac.uk/2020/09/14/new-4m-study-to-advance-understanding-of-severe-coronavirus-infection/), will sequence and analyze samples from humans and animals to create profiles of various coronaviruses, including SARS-CoV-2, which causes COVID-19. As part of this three-year project, investigators will evaluate how in vitro models of coronavirus infection, including human organs-on-chips, compare to in vivo responses in animal models and humans. Ultimately, these in vitro models may be employed in the development of biologics, drugs, or devices to treat COVID-19.

### Grants to support development of PBPK models

Tags: FDA, IVIVE

In January 2021, FDA CDER announced availability of grants to support development of PBPK models (https://grants.nih.gov/grants/guide/rfa-files/RFA-FD-21-012.html) for bioequivalence studies for new generic drugs. CDER requested that proposals include scientifically justified IVIVE strategies, discuss how the models will address population variability, and describe a plan for how models would be verified and validated. The intent was to award a total of $600,000 over 2 years to one or two awardees.

### Challenge to develop ecotoxicity gene expression assay

Tags: DoD, EPA, ecotoxicity

In March 2020, EPA announced a partnership with DoD, international governments, and industry to sponsor the EcoTox TARGET innovation challenge (https://www.epa.gov/innovation/ecotox-target-challenge). The challenge would award $300,000 to the applicant who successfully developed a low-cost high-throughput technology for measuring global gene expression in samples from four common aquatic toxicity test organisms. The winner will be announced in spring 2022.

## International Interactions

Efforts by individual countries to develop NAMs will have little impact without international adoption of the new methods. To advance international adoption, ICCVAM and its member agencies interact frequently with international partners to facilitate harmonization and regulatory acceptance.

### Contributions to OECD activities

Tags: ICCVAM, IATA, skin sensitization, eye irritation, endocrine disruptors, developmental toxicity, neurotoxicity

ICCVAM member agencies participate in the development and review of chemical testing guidelines issued by the OECD Test Guidelines Programme (http://www.oecd.org/env/ehs/testing/oecd-guidelines-testing-chemicals-related-documents.htm). OECD test guidelines are used by government, industry, and independent laboratories of the 38 OECD member countries to assess chemical safety. The U.S. National Coordinators for the OECD Test Guidelines Programme, who are members of ICCVAM, solicit and collate U.S. comments on draft test guidelines and other documents of the Test Guidelines Programme. The National Coordinators represent the United States at the annual meeting of the Working Group of National Coordinators and in other test guideline development activities. One or more ICCVAM subject matter experts may join the U.S. National Coordinators at this meeting. In 2020 and 2021, ICCVAM agencies commented on draft OECD documents through the U.S. National Coordinators. ICCVAM members and/or NICEATM staff also supported the Test Guidelines Programme during 2020 and 2021 by:

- Contributing to a proposal to update OECD Test Guideline 496 (https://www.oecd-ilibrary.org/environment/test-no-496-in-vitro-macromolecular-test-method-for-identifying-chemicals-inducing-serious-eye-damage-and-chemicals-not-requiring-classification-for-eye-irritation-or-serious-eye-damage_970e5cd9-en) for in vitro test methods to identify eye irritants to add the OptiSafe test method to the guideline.
- Serving on an expert group developing a guideline for defined approaches for skin sensitization. This group supported the development of Guideline 497, Defined Approaches for Skin Sensitisation (https://www.oecd-ilibrary.org/environment/guideline-no-497-defined-approaches-on-skin-sensitisation_b92879a4-en), issued in 2021. Guideline 497 is the first internationally harmonized guideline to describe a non-animal defined approach that can be used to replace an animal test to identify skin sensitizers. NICEATM and ICCVAM scientists are currently contributing to two proposals to update Guideline 497 to include new information sources for existing defined approaches, and new defined approaches for quantitative risk assessment.
- Participating in a group developing a Case Study on the Use of an IATA for Identifying Androgen Receptor Active Chemicals, which has been submitted to the OECD Working Party on Hazard Assessment.
- Contributing to a retrospective review of available data and information to support an OECD test guideline for a human reconstructed epidermis model for phototoxicity testing. Test Guideline 498, In Vitro Phototoxicity - Reconstructed Human Epidermis Phototoxicity Test Method (https://www.oecd-ilibrary.org/environment/test-no-498-in-vitro-phototoxicity-reconstructed-human-epidermis-phototoxicity-test-method_7b2f9ea0-en), was adopted in June 2021.
- Serving on the Validation Management Group – Non-animal, which focuses on evaluation of new methods for identifying endocrine disruptors.
- Serving on an expert group considering test batteries for developmental neurotoxicity.

### Participation in the International Cooperation on Alternative Test Methods

Tags: ICCVAM, skin sensitization, IATA, antibodies, IVIVE, eye irritation, acute toxicity

The International Cooperation on Alternative Test Methods (https://ntp.niehs.nih.gov/go/icatm) (ICATM) was created to foster dialogue among national validation organizations. This dialogue facilitates international cooperation in the critical areas of validation studies, independent peer review, and development of harmonized recommendations. ICATM includes member organizations from the European Union, United States, Japan, Canada, and South Korea. Brazil and China have been participating in ICATM since 2015 as observers.

#### ICATM Participant Organizations

- ICCVAM (https://ntp.niehs.nih.gov/whatwestudy/niceatm/iccvam/index.html) is an interagency committee of the U.S. government that coordinates technical reviews of alternative test methods and cross-agency activities relating to validation, acceptance, and harmonization of test methods. NICEATM (https://ntp.niehs.nih.gov/go/niceatm) administers ICCVAM and provides scientific support for its activities.
- EURL ECVAM (https://eurl-ecvam.jrc.ec.europa.eu/) (European Union Reference Laboratory for Alternatives to Animal Testing) is a unit within the Institute of Health and Consumer Protection in the European Union’s Joint Research Centre. EURL ECVAM coordinates the validation of alternative test methods in the European Union.
- JaCVAM (https://www.jacvam.jp/en/index.html) (Japanese Center for the Validation of Alternative Methods) coordinates the evaluation of alternative test methods for the Japanese National Institute of Health Sciences, its parent organization.
- Health Canada (https://www.canada.ca/en/health-canada.html)’s Environmental Health Science and Research Bureau coordinates the evaluation of alternative test methods in Canada. The Canadian Centre for Alternatives to Animal Methods (http://www.uwindsor.ca/vp-research/350/canadian-centre-alternatives-animal-methods) and its subsidiary, the Canadian Centre for the Validation of Alternative Methods, participate as partners with Health Canada in ICATM activities.
- KoCVAM (https://norecopa.no/inventory3rs/korean-center-for-the-validation-of-alternative-methods) (Korean Center for the Validation of Alternative Methods) is part of the National Institute of Food and Drug Safety Evaluation of the South Korean Food and Drug Administration.
- BraCVAM (http://www.bracvam.fiocruz.br/) (Brazilian Center for the Validation of Alternative Methods) functions as the focal point within Brazil to identify or receive requests for test method validation. It works to implement appropriate validation studies with the National Network of Alternative Methods to the Use of Animals within the Brazilian Ministry of Science, Technology, Innovations, and Communications.

An ICATM coordination meeting was hosted virtually by JaCVAM in October 2020. Representatives from the United States, European Union, Canada, Japan, South Korea, and Taiwan presented updates on recent activities. Discussion topics included.

- The concept of standards and approaches to validation that could replace multi-laboratory studies.
- Activities to address European recommendations on use of non-animal derived antibodies.
- Development of detailed review papers and IATA.
- Human-relevant approaches to assessing the eye irritation potential of agrochemical formulations.

In 2020, EURL ECVAM issued recommendations on use of non-animal derived antibodies. The EURL ECVAM recommendations were based on a scientific advisory committee review that found that:

- Animal-free technologies are able to produce affinity reagents with equal or better quality than that offered by antibodies produced using the conventional animal-based methods.
- Use of animal-free affinity reagents provides scientific benefits.

Use of animal-free affinity reagents was discussed at the 2020 ICCVAM Communities of Practice webinar. A webinar series (https://www.thepsci.eu/antibody-webinars/) co-organized by NICEATM, EURL ECVAM, and the PETA Science Consortium International e.V. and presented in July-November 2020 explored international activities in this area in more detail.

ICATM partner representatives from the United States, Japan, and the European Union presented updates at the October 2021 “International Symposium on Alternatives to Animal Testing in Taiwan (http://nehrc.nhri.org.tw/taat/2021-ISAAT-TW.php).”

ICCVAM member agency scientists serve on management teams or peer review panels for test method validation studies conducted by ICATM partners. Since 2018, a NICEATM scientist has been serving on the management team for a validation study led by JaCVAM. The validation management team has been evaluating the sensitivity and specificity of luciferase-based assays for the detection of relevant cytokines as individual components of the multi-immunotox assay. The multi-immunotox assay is intended to be used as a comprehensive screening assay to identify potentially immunotoxic chemicals by assaying the activity of T cells and dendritic cells.

The following ICCVAM workgroups had ICATM member liaison representatives during 2020 and 2021.

ICCVAM Workgroup | ICATM Organizations with Liaison Members
Acute Toxicity Workgroup | EURL ECVAM, KoCVAM
In Vitro to In Vivo Extrapolation Workgroup | JaCVAM
Read Across Workgroup | JaCVAM

### Participation on ICH

Tags: FDA, carcinogenicity, developmental toxicity

FDA CDER pursues international harmonization of nonclinical recommendations for pharmaceutical development through its engagement with the International Council for Harmonisation of Technical Requirements for Pharmaceuticals for Human Use (ICH). ICH brings together regulatory authorities and the pharmaceutical industry to discuss scientific and technical aspects of drug registration. ICH’s mission is to achieve greater harmonization worldwide to ensure that safe, effective, and high-quality medicines are developed and registered in the most resource-efficient manner. These activities prevent repetition of studies and reduce and refine animal use in overall drug development. New guidance recently approved will continue to contribute to the 3Rs as will future guidance currently being developed or revised.

FDA solicited comment in October 2021 on a draft addendum to ICH guidance on carcinogenicity (https://database.ich.org/sites/default/files/ICH_S1BR1_Step2_DraftGuideline_2021_0510.pdf) testing and published guidance aligned with ICH documents on evaluation of developmental and reproductive toxicity as discussed elsewhere in this report.

### Accelerating the Pace of Chemical Risk Assessment

Tags: EPA

The advent of NAMs for generating safety information on chemicals provides an opportunity to assess what chemical risk assessment should look like in the 21st century. EPA played a leadership role in Accelerating the Pace of Chemical Risk Assessment (Kavlock et al. 2018 (https://pubs.acs.org/doi/10.1021/acs.chemrestox.7b00339)), an international activity to bring together regulators from agencies such as the European Chemicals Agency and Health Canada to discuss progress in applying new tools to prioritization, screening, and application to quantitative risk assessment of differing levels of complexity. During 2020 and 2021, the collaboration developed case studies on the development and applications of NAMs for chemical risk assessment, one of which was described in a paper published by EPA scientists and collaborators (Paul Friedman et al. 2020 (https://academic.oup.com/toxsci/article/173/1/202/5571376)). These collaborations examined how NAMs might transform regulatory evaluation of chemicals and help overcome barriers to acceptance by increasing confidence in the use and acceptance of NAMs in regulatory chemical risk assessment.

### Review of animal testing requirements in World Health Organization guidelines and recommendations for biologics

Tags: FDA, NIEHS, biologics

Biologics such as vaccines, cytokines, enzymes, and hormones are tested routinely after approval to ensure the safety and potency of products. Many of these tests currently require the use of animals, and a large number of animals are used for this purpose each year.

FDA and NIEHS are supporting a project led by the World Health Organization and NC3Rs to carry out an independent and comprehensive review of animal use requirements within World Health Organization guidelines for biologics and to make recommendations for where non-animal approaches can be adopted. The project is currently in an information-gathering phase. In 2021, a survey of biologics manufacturers was conducted to better understand the opportunities and barriers to adoption of replacement, reduction, and refinement alternatives and use of non-animal approaches in quality control, batch, and lot release testing of biologics. A similar survey of national regulatory authorities and national control laboratories will be conducted in early 2022. Data collected will be anonymized and published in an appropriate scientific peer-reviewed journal or as a report on the NC3Rs website, and/or presented at scientific meetings or webinars.

## Collaborations

The 2018 ICCVAM Strategic Roadmap (https://ntp.niehs.nih.gov/go/natl-strategy) identified stakeholder engagement as critically important to advancing development and use of alternative methods. The articles below and others throughout this document describe collaborations to advance alternatives within agencies, among agencies, and between agencies and stakeholders.

### Activities of the Tri-Services Toxicology Consortium

Tags: DoD, VA ORD, inhalation toxicity, skin sensitization, QSAR, mixtures toxicity

The mission of the Tri-Services Toxicology Consortium is to communicate, coordinate, and optimize toxicology needs throughout DoD by providing a central point of contact to DoD toxicology resources. The Consortium currently includes over 200 individuals from 11 organizations within DoD, seven of which have laboratories. Given the shared missions, individuals from the Veterans Administration and Department of Homeland Security are also invited to participate.

The Consortium convened four meetings during 2020 and 2021. These meetings began with brief presentations of new work including efforts in toxicity of novel compounds in various in vitro and in vivo systems, improving in silico predictions of molecular targets, characterization of toxicity using evidence integration techniques, advances in PBPK modeling and development, use of NAMs within phased approaches to toxicity data collection and hazard assessment, and new developments in understanding the mechanism for toxicity for chemicals of military interest. Significant recent efforts included:

- Substance-specific technical reviews and publications concerning chromium, lead, trichloroethylene, and selected PFAS.
- Identification of toxicity and biomarkers of exposure to diesel exhaust using a circulated human multi-tissue organoid platform.
- Investigations into biomarkers of pulmonary toxicants.
- Evaluation of fluorine-free aqueous-film forming foam formulations.
- Use of in silico methods, including QSAR models, to predict skin sensitization, to address mixtures, and to derive metabolic parameters from in vitro data.
- Continued DoD technical representation on relevant government and scientific committees.

### Botanical Safety Consortium

Tags: FDA, NIEHS, cardiotoxicity, mixtures toxicity

In 2019, FDA, NIEHS, and the non-profit Health and Environmental Sciences Institute signed a memorandum of understanding establishing the Botanical Safety Consortium (http://botanicalsafetyconsortium.org/). The Consortium includes over 20 participants from industry, academia, and government to promote scientific advances in evaluating the safety of botanical ingredients and mixtures in dietary supplements. This group will look at novel ways to use cutting-edge toxicology tools, including alternatives to animal testing, to promote the goals of safety and effectiveness.

The Botanical Safety Consortium held virtual annual meetings in 2020 and 2021. The 2020 meeting provided a forum to articulate the needs for a scientific approach to assessing botanicals safety and refine the goals of the Consortium. Presenters at the 2021 meeting described a project to characterize cardiotoxicity of botanicals and provided overviews of applications of in silico modeling and NAMs to predict toxicity of botanicals.

### FDA Alternative Methods Working Group

Tags: FDA

In 2019, FDA chartered an Alternative Methods Working Group (https://www.fda.gov/science-research/about-science-research-fda/advancing-alternative-methods-fda) with representatives from all of FDA. The goals of this working group are to:

- Strengthen FDA’s long commitment to promoting the development and use of new technologies and to reduce animal testing.
- Discuss new alternative in vitro/in silico/in vivo methods across FDA.
- Interact with federal government partners and other global stakeholders to facilitate discussion and development of draft performance criteria for such assays.

During 2020 and 2021, the working group coordinated an internal webinar series (https://www.fda.gov/science-research/about-science-research-fda/fda-webinar-series-alternative-methods-showcasing-cutting-edge-technologies-disease-modeling) on alternative methods that provided test method developers the opportunity to present their new methods to FDA scientists.

The 2021 FDA report, Advancing Regulatory Science at FDA: Focus Areas of Regulatory Science (https://www.fda.gov/media/145001/download), outlined areas needing continued targeted investment in regulatory science research to foster the development of innovative products, provide data and methods to inform regulatory decision-making, and improve guidance to sponsors. One of those priority areas was “Advancing Novel Technologies to Improve Predictivity of Non-clinical Studies and Replace, Reduce, and Refine Reliance on Animal Testing.”

### MPSCoRe Working Group

Tags: DoD, NIEHS, NIH, COVID-19, MPS

In January 2021, NICEATM, the National Institute of Allergy and Infectious Diseases, the U.S. Army Combat Capabilities Development Command Chemical Biological Center, and NCATS established the MPS for COVID Research (MPSCoRe) Working Group (https://ntp.niehs.nih.gov/go/mps) in collaboration with NC3Rs. The MPSCoRe Working Group coordinates the use of MPS to reduce animal use in studies of COVID-19 and future emerging infectious diseases. Members include researchers, MPS model developers, therapeutic/vaccine manufacturers, and international regulators. A July 2021 feature article in Drug Discovery Today (Kleinstreuer and Holmes 2021) reviews MPSCoRe Working Group activities in the context of the broader effort to apply MPS to the development of therapies for COVID-19.

Activities of the MPSCoRe Working Group have included:

- An organizational meeting in January 2021.
- A workshop in April 2021 that featured presentations on the themes of testing therapeutics and understanding disease mechanisms.
- A tutorial in May 2021 on how to use the University of Pittsburgh Microphysiological Systems Database to find and share data on COVID-19 projects.
- A series of four webinars from June-September 2021 in which working group members described applications of MPS technologies to understanding the mechanisms of COVID-19 disease and assessing the safety and efficacy of potential novel therapeutics.
- A meeting with representatives of the World Health Organization in December 2021 to discuss research needs relevant to the biology and treatment of the Omicron SARS-CoV-2 variant and the potential for MPS to provide human-relevant platforms for rapidly addressing those needs.

### The Tox21 compound library: collaborative chemistry advancing toxicology

Tags: EPA, FDA, NIEHS, NIH, Tox21, metrics

Since 2009, the Tox21 project has screened about 8,500 chemicals in more than 70 high-throughput assays, generating upward of 100 million data points, with all data publicly available. Underpinning this public effort is the largest compound library ever constructed specifically for improving understanding of the chemical basis of toxicity across research and regulatory domains. The different programmatic objectives of the Tox21 partners led to three distinct, overlapping compound libraries that, when combined, not only covered a diversity of chemical structures, use categories, and properties but also incorporated many types of compound replicates. A 2021 publication (Richard et al. 2021 (https://pubmed.ncbi.nlm.nih.gov/33140634/)) describes the history of development of the Tox21 “10K” chemical library and data workflows implemented to ensure quality chemical annotations and allow for various reproducibility assessments. The paper presents cheminformatics profiles that demonstrate how the three partner libraries complement one another to expand the reach of each individual library, as reflected in coverage of regulatory lists, predicted toxicity endpoints, and physicochemical properties.

### National Academies Panel on variability and relevance of mammalian toxicity tests

Tags: EPA, NIEHS, NIST

ICCVAM members from NIEHS and NIST are serving on a committee convened by the National Academies of Sciences, Engineering, and Medicine for the consensus study, “Variability and Relevance of Current Laboratory Mammalian Toxicity Tests and Expectations for New Approach Methods (NAMs) for use in Human Health Risk Assessment (https://www.nationalacademies.org/our-work/variability-and-relevance-of-current-laboratory-mammalian-toxicity-tests-and-expectations-for-new-approach-methods--nams--for-use-in-human-health-risk-assessment).” This study was undertaken by the National Academies in response to a request from EPA. It will review the variability and relevance of existing mammalian toxicity tests, specifically in the context of human health risk assessment. The review will support the establishment of data-driven and science-based expectations for NAMs based on the variability and relevance of the traditional toxicity testing models.

The committee was established in 2021 and has held two public meetings. The first of these on September 23 included discussions with EPA staff regarding the statement of task, reasons for the committee’s study, and description of the types of committee recommendations that would be most useful, as well as a brief public comment period. A workshop on December 9 featured expert presentations addressing several questions relevant to the study:

- How are traditional toxicity studies used in informing chemical safety decisions?
- What do we know about the variability and concordance of traditional mammalian toxicity studies?
- What are the needs and expectations of different stakeholders?

Proceedings (https://nap.nationalacademies.org/catalog/26496/new-approach-methods-nams-for-human-health-risk-assessment-proceedings) from this workshop will be published in 2022. The committee will hold additional public meetings in 2022 and expects to issue a report with recommendations late in the year.

### Environmental Health Language Collaborative

Tags: NIEHS, EPA

NIEHS and EPA are fostering a community-driven initiative, the Environmental Health Language Collaborative (https://www.niehs.nih.gov/research/programs/ehlc/), to advance integrative environmental health research by developing and promoting adoption of a harmonized language. This initiative will facilitate answering large-scale complex research questions that require integration of multiple disparate data sources by developing language standards for describing data and biomedical knowledge. Several webinar events were held during 2021 to help set the stage, begin discussions, and draft plans for how to make progress on the Collaborative’s goals. The Collaborative welcomes diverse representation of expertise, needs, and scientific interests to make this a successful and sustainable community, and those interested are invited to join its email distribution list (https://list.nih.gov/cgi-bin/wa.exe?SUBED1=EHSCOMMONLANGUAGE&A=1).

### FDA partnership to apply lung chips to safety evaluation of COVID-19 vaccines and therapies

Tags: FDA, COVID-19, MPS

In October 2020, FDA entered into a Cooperative Research and Development Agreement (https://www.emulatebio.com/press/fda-organ-chip-crada-2020) with Emulate, Inc. to enable multiple studies using Emulate’s Organ-Chips across FDA offices in priority research areas. Organ-Chips are in vitro systems that recreate the natural physiology of specific human tissues and organs. Some projects will evaluate COVID-19 vaccines or investigate human immune response against SARS-CoV-2, the virus that causes COVID-19. Under the agreement, FDA will use a range of Organ-Chips to study the safety, efficacy, and mechanisms of action of drugs regulated by the FDA. This new agreement follows the successful completion of the first Emulate Cooperative Research and Development Agreement with the FDA initiated in 2017 that focused on toxicity studies using Emulate’s Liver-Chip.

### U.S. Department of Veterans Affairs Office of Research and Development joins ICCVAM as new member agency

Tags: VA ORD, ICCVAM

In October 2020, the U.S. Department of Veterans Affairs Office of Research and Development (VA ORD) joined ICCVAM to become the 17^th^ ICCVAM member agency. Joining ICCVAM will help VA ORD to coordinate efforts with other federal agencies in replacing, reducing, and refining animal use. It is part of an overall agency plan to reduce animal use while improving predictions of human health hazard.

### Activities of the In Silico Carcinogenicity Protocol Workgroup

Tags: FDA, NIEHS, carcinogenicity

Scientists within the FDA Center for Devices and Radiological Health, FDA CDER, and NIEHS participate in an international interdisciplinary consortium to develop publicly available in silico protocols to support the hazard assessment of major toxicological endpoints. Within that consortium, the In Silico Carcinogenicity Protocol Workgroup has focused on developing an in silico protocol for the hazard assessment of carcinogens based on the 10 key characteristics of carcinogens (Smith et al. 2016 (https://doi.org/10.1289/ehp.1509912)). The workgroup has published an assessment (Tice et al. 2021 (https://www.sciencedirect.com/science/article/pii/S2468111321000396)) of how current in silico methods address each of the key characteristics and where additional methods or data resources need to be developed. The workgroup is currently developing case studies on four chemicals to determine whether data available for current in silico approaches would be sufficient to generate predictions of in vivo bioassay outcomes. In a related activity, members of the workgroup are compiling a review of receptor-mediated carcinogenesis that will examine the degree to which interaction with nuclear receptors is a key driver of chemically induced carcinogenesis, as opposed to a downstream effect.

### Activities of the Carcinogenesis Health Effects Innovation Program

Tags: DoD, DOE, NIEHS, carcinogenicity

Approximately one in three people will be diagnosed with cancer at some point in their lifetime. Despite tremendous progress in screening and treatment methods, cancer is still the second most common cause of death in the United States and the leading health concern of the American public.

The Carcinogenicity Health Effects Innovation Program (CarciHEI) is a program within DNTP. The CarciHEI is developing innovative approaches to quickly and efficiently assess the cancer risk posed by environmental exposures to help identify and mitigate the factors contributing to these increases. The program’s goal is to identify early molecular biomarkers of preneoplasia and neoplasia and develop in vitro screening assays that can predict a cancer hazard.

The CarciHEI is collaborating with the Murtha Cancer Center at Walter Reed National Military Medical Center and the DoD Serum Repository to identify cohorts of service members diagnosed with cancer believed to be related to environmental exposures. Through an interagency agreement with the DOE Pacific Northwest National Laboratory, the CarciHEI will conduct proteomic analysis of serum samples collected every 2 years from these service members with the hope of identifying biomarkers of preneoplastic and early neoplastic events that contribute to the subsequent development of cancer.