# Utilization

Federal agencies need to take an active role in facilitating the successful adoption and use of NAMs, both within the government and internationally. ICCVAM agencies strive to provide clear guidance on the use and acceptance of data from new methods. Where possible, they implement approaches to reduce and replace animal use.

## Assessments of Agency Needs and Practices

The 2018 ICCVAM Strategic Roadmap (https://ntp.niehs.nih.gov/go/natl-strategy) identified the definition of agency information needs as a key step in its implementation. ICCVAM member agencies are collaborating both within ICCVAM workgroups and independently to define agency information needs and make those needs known to stakeholders. Areas considered in 2020 and 2021 included carcinogenicity, liver and kidney toxicity, ecotoxicity, and nanomaterials toxicity.

### FDA/CDER perspective on use of new approach methodologies (NAMs) in drug development

Tags: FDA

Nonclinical testing of human pharmaceuticals is conducted to assess the safety of compounds to be studied in human clinical trials and for marketing of new drugs. Recent advances in science have led to the emergence of numerous NAMs for nonclinical testing that are currently being used in various aspects of drug development. A paper by scientists within the FDA Center for Drug Evaluation and Research (CDER) and the FDA National Center for Toxicological Research (Avila et al. 2020 (https://www.sciencedirect.com/science/article/abs/pii/S027323002030088X)) discusses CDER’s view on the opportunities and challenges of using NAMs in drug development, especially for regulatory purposes. The paper includes examples where NAMs are currently being used in nonclinical safety assessments and where they may supplement or enhance current testing methods.

### In silico approaches in carcinogenicity hazard assessment: Current status and future needs

Tags: FDA, NIEHS, carcinogenicity

Historically, identifying carcinogens has relied primarily on tumor studies in rodents, which require enormous resources in both money and time. In silico models have been developed for predicting rodent carcinogens but have not yet found general regulatory acceptance, in part due to the lack of a generally accepted protocol for performing such an assessment as well as limitations in predictive performance and scope. There remains a need for additional, improved in silico carcinogenicity models, especially ones that are more human-relevant, for use in research and regulatory decision-making. As part of an international effort to develop in silico toxicological protocols, FDA and NIEHS scientists participated in a consortium of toxicologists, computational scientists, and regulatory scientists across several industries and governmental agencies to evaluate the extent to which in silico models exist for each of the recently defined 10 key characteristics of carcinogens. A position paper developed by the group (Tice et al. 2021 (https://www.sciencedirect.com/science/article/abs/pii/S2468111321000396)) summarizes the current status of in silico tools for the assessment of each key characteristic and identifies the data gaps that need to be addressed before a comprehensive in silico carcinogenicity protocol can be developed for regulatory use.

### In silico approaches in organ toxicity hazard assessment: Current status and future needs in predicting liver toxicity

Tags: ATSDR, FDA, NIEHS, hepatotoxicity

Hepatotoxicity is one of the most frequently observed adverse effects resulting from exposure to a xenobiotic, and one of the major reasons for drug withdrawals, clinical failures, and discontinuation of drug candidates. Faster and cheaper methods to assess hepatotoxicity that are both more sustainable and more informative are critically needed. A review (Bassan et al. 2021) coauthored by ATSDR, FDA, and NIEHS scientists summarizes biological mechanisms and processes underpinning hepatotoxicity and describes experimental approaches to support the prediction of hepatotoxicity, including toxicokinetic considerations. The paper describes the increasingly important role of in silico approaches and highlights challenges to the adoption of these methods, including the lack of a commonly agreed upon protocol for performing such an assessment and the need for in silico solutions that take dose into consideration. A proposed framework for the integration of in silico and experimental information is provided, along with a case study describing how computational methods have been used to successfully respond to a regulatory question concerning non-genotoxic impurities in chemically synthesized pharmaceuticals.

### In silico approaches in organ toxicity hazard assessment: Current status and future needs for predicting heart, kidney, and lung toxicities

Tags: ATSDR, FDA, NIEHS, hepatotoxicity, cardiotoxicity, inhalation toxicity

The kidneys, heart, and lungs are vital organ systems evaluated as part of acute or chronic toxicity assessments. New methodologies are being developed to predict adverse effects based on in vitro and in silico approaches. A review coauthored by ATSDR, FDA, and NIEHS scientists considered the current state of the art in predicting these organ toxicities (Bassan et al. 2021). The review outlines the biological basis, processes, and endpoints for kidney toxicity, pulmonary toxicity, respiratory irritation and sensitization, and functional and structural cardiac toxicities. The review also covers current experimental approaches, including off-target panels from secondary pharmacology batteries. Current in silico approaches for prediction of these effects and mechanisms are described as well as obstacles to the use of in silico methods. Ultimately, a commonly accepted protocol for performing in silico assessments would be a valuable resource to expand the use of such approaches across different regulatory and industrial applications. The review identifies factors impeding the widespread deployment of in silico approaches, including lack of a comprehensive understanding of the mechanisms of toxicity, limited in vitro testing approaches, limited in vivo databases suitable for modeling, a limited understanding of how to incorporate ADME considerations into the overall process, a lack of in silico models designed to predict a safe dose, and a need for an accepted framework for organizing the key characteristics of these organ toxicants.

### Assessment of U.S. federal agency ecotoxicity information and testing needs

Tags: ICCVAM, DoD, DOI, EPA, FDA, NIEHS, NIST, USDA, ecotoxicity

U.S. regulatory and research agencies use ecotoxicity test data to assess the hazards and risks associated with substances that may be released into the environment, including but not limited to industrial chemicals, pharmaceuticals, pesticides, food additives, and cosmetics. These data are used to conduct hazard assessments and evaluate potential risks to non-target animals and plants. To identify opportunities for regulatory uses of non-animal replacements for ecotoxicity tests, the needs and uses for these types of test data must first be clarified. The ICCVAM Ecotoxicology Workgroup prepared a review (Ceger et al. 2022 (https://doi.org/10.1016/j.yrtph.2022.105195)) that identifies the ecotoxicity test data relied upon by U.S. federal agencies. The review describes the standards, test guidelines, guidance documents, and endpoints that are used to address each of the responding agencies’ regulatory and research needs regarding ecotoxicity testing in the context of their application to decision-making. This information will be useful for coordinating efforts to develop and implement alternative test methods to reduce, refine, or replace animal use in chemical safety evaluations.

### U.S. federal agency interests and key considerations for new approach methodologies for nanomaterials

Tags: ICCVAM, CPSC, DoD, EPA, FDA, NIEHS, NIOSH, NIST, nanomaterials

Engineered nanomaterials (ENMs) come in a wide array of shapes, sizes, surface coatings, and compositions, and often possess novel or enhanced properties compared to larger-sized particles of the same elemental composition. To ensure the safe commercialization of products containing ENMs, it is important to thoroughly understand their potential risks. Given that ENMs can be created in an almost infinite number of variations, it is not feasible to conduct in vivo testing on each type of ENM. Instead, NAMs such as in vitro or in chemico test methods may be needed, given their capacity for high-throughput testing, lower cost, and ability to provide information on toxicological mechanisms. However, the different behaviors of ENMs compared to dissolved chemicals may challenge safety testing of these substances using NAMs. The ICCVAM Nanomaterials Workgroup queried ICCVAM member agencies about what types of ENMs are of agency interest and whether there is agency-specific guidance for ENMs toxicity testing (Petersen et al. 2021). To support the ability of NAMs to provide robust results in ENM testing, two key issues in the usage of NAMs, namely dosimetry and interference/bias controls, are thoroughly discussed.

### Applying IVIVE to facilitate the use of in vitro toxicity data in risk assessment and decision-making

Tags: ICCVAM, ATSDR, CPSC, DoD, EPA, FDA, NIEHS, NIST, NLM, IVIVE

In vitro toxicity assays are being applied to transform toxicology from an observational to a predictive science, improve throughput, and reduce costs. The qualitative linkage between in vitro and in vivo toxicity endpoints can be strengthened via application of IVIVE, which relates an in vitro concentration associated with bioactivity to an external exposure level. In some contexts, applications of IVIVE have advanced past the exploratory research stage and are beginning to gain acceptance for risk assessment of chemicals. The ICCVAM IVIVE Workgroup requested information from ICCVAM member agencies regarding the extent and context of their use of IVIVE. Surveyed agencies were also asked about programmatic needs, data gaps, and agency-specific guidance documents or publications related to IVIVE, as well as for information about modeling tools or software they had used or may use for facilitating IVIVE analysis and decision-making. This information was compiled into a review summarizing the workgroup’s findings, current challenges, and future needs (Chang et al. 2022 (https://doi.org/10.3390/toxics10050232)). The review also proposes operational definitions for IVIVE, presents literature examples for several common toxicity endpoints, and highlights implications of IVIVE use in decision-making processes.

### Request for information on efficacy testing of ectoparasiticide products

Tags: NIEHS

In a December 2021 Federal Register notice (86 FR 72251 (https://www.federalregister.gov/d/2021-27581)), NICEATM requested available data and information on approaches and/or technologies currently used for efficacy testing of ectoparasiticide products, such as products to prevent flea and tick infestations on dogs and cats. Submitted information will be used to assess the state of the science and determine technical needs for non-animal test methods used to evaluate the efficacy of ectoparasiticides on dogs and cats and to facilitate their incorporation into a testing strategy for regulatory purposes.

## Initiatives to Replace or Reduce Animal Use

Reducing or eliminating animal testing is a key goal of the 2018 ICCVAM Strategic Roadmap (https://ntp.niehs.nih.gov/go/natl-strategy). To this end, ICCVAM agencies that conduct chemical safety testing develop and use approaches that reduce or replace animal use. Likewise, ICCVAM agencies that require their stakeholders to conduct testing are reducing required animal use by developing criteria for waiving tests.

### EPA New Approach Methods Work Plan

Tags: EPA, metrics

In June 2020, EPA released its New Approach Methods Work Plan (https://www.epa.gov/chemical-research/epa-new-approach-methods-work-plan-reducing-use-animals-chemical-testing), which was created in response to the EPA Administrator’s 2019 directive to prioritize activities that will reduce the use of animal testing while continuing to protect human health and the environment. The work plan was developed by experts across the agency to set the objectives and strategies for using new approach methods to meet the ambitious goals set out in the Administrator’s directive.

An update of the work plan (https://www.epa.gov/system/files/documents/2021-11/nams-work-plan_11_15_21_508-tagged.pdf) was released in December 2021. The updated work plan addresses recommendations made by the ICCVAM Metrics Workgroup in its report, “Measuring U.S. Federal Agency Progress Toward Implementation of Alternative Methods in Toxicity Testing. (https://ntp.niehs.nih.gov/whatwestudy/niceatm/iccvam/metric/index.html)” In its updated work plan, EPA commits to reporting summary metrics on reducing vertebrate animal testing and use annually on its website (https://www.epa.gov/pesticide-science-and-assessing-pesticide-risks/strategic-vision-adopting-new-approach-0) beginning in the fourth quarter of 2022.

### EPA guidance for waiving of toxicity tests on animal skin

Tags: EPA, acute toxicity, metrics

In December 2020, EPA published final guidance (https://www.govinfo.gov/content/pkg/FR-2021-03-17/pdf/2021-05535.pdf) that will allow researchers to forego testing chemicals for acute systemic toxicity on animal skin in certain circumstances. The “Final Guidance for Waiving Acute Dermal Toxicity Tests for Pesticide Technical Chemicals and Supporting Retrospective Analysis” allows for data waivers for acute dermal systemic toxicity studies for single active ingredients used to develop end-use products other than fumigants and rodenticides. The document includes a policy statement to waive all acute lethality dermal studies for single active ingredients in many cases.

This guidance supports EPA efforts to identify opportunities for test waivers that can reduce animal use for testing required for pesticide registration. It was based on a retrospective analysis conducted by EPA and collaborators, which concluded that such studies provide little to no added value in regulatory decision-making when an acute oral toxicity study has been conducted. This guidance is expected to save up to 750 test animals annually from unnecessary testing, as well as EPA, industry, and laboratory resources.

### Retrospective analysis of triple pack studies for dermal absorption

Tags: EPA, NIEHS, acute toxicity

Substances can cause acute systemic toxicity when absorbed through the skin. Dermal systemic toxicity is in turn driven by the ability of a substance to penetrate the skin. Dermal absorption can be estimated using the “triple pack,” a study design that combines in vivo rat, in vitro rat, and in vitro human data to calculate an estimated human dermal absorption factor.

To assess the feasibility of deriving a dermal absorption factor using only in vitro data, NICEATM and EPA conducted a retrospective evaluation of agrochemical formulations to compare the dermal absorption factors derived from each method (Allen et al. 2021). The dermal absorption factor derived from the human in vitro study was also compared to the dermal absorption factor generated from the triple pack approach. Absorption through in vitro human skin was found to be similar to or less than that observed in rat skin for all formulations. For most of the formulations evaluated:

- The in vitro rat method generated a similar or higher dermal absorption factor value than the in vivo method.
- The human in vitro method provided a similar or higher estimate of dermal absorption than the triple pack approach.

This analysis supports potentially using in vitro data alone for dermal absorption factor derivation for human health risk assessment of pesticides. While it is preferable to use data from human skin for human health risk assessments, human in vitro data are not always available. The analysis also demonstrated that estimates of dermal absorption based on in vitro rat data are at least as protective as in vivo rat data, and thus could also be considered adequate for use in establishing dermal absorption factors.

### Replacement of in vivo leptospirosis vaccine potency testing in the United States

Tags: NIEHS, USDA, biologics

A 2012 workshop co-organized by NIEHS, USDA, and partner organizations sought to develop an international strategy to replace the use of animals in tests required during the assessment of veterinary leptospirosis vaccines (Johnson et al. 2013 (https://www.sciencedirect.com/journal/biologicals/vol/41/issue/5)). Workshop participants gave special attention to the barriers remaining to replace the in vivo vaccine potency test in hamsters. At the time of the workshop, in vitro methods were not widely used as replacements for the in vivo potency test, but advances in both technology and regulatory arenas have since increased their acceptance and use. NIEHS and USDA scientists prepared a review of recent progress (Rogers et al. 2022 (https://doi.org/10.1016/j.biologicals.2022.05.001)) to reduce the use of hamsters in leptospirosis vaccine batch potency testing, as well as obstacles remaining to completely replace the use of hamsters with accepted in vitro methods.

### EPA evaluation of avian toxicity tests for pesticide registration

Tags: EPA, acute toxicity, ecotoxicity, metrics, oral toxicity

In a February 2020 news release (https://www.epa.gov/newsreleases/epa-takes-important-step-reduce-unnecessary-animal-testing), EPA announced that it had finalized guidance to reduce testing of pesticides on birds (https://www.epa.gov/sites/default/files/2020-02/documents/final-waiver-guidance-avian-sub-acute-dietary.pdf) when registering conventional outdoor pesticides. The guidance describes the results and implications of a retrospective study conducted by EPA and People for the Ethical Treatment of Animals (Hilton et al. 2019 (https://pubmed.ncbi.nlm.nih.gov/30922892/)). The study explored the quantitative and qualitative contributions of risk assessment methods using single oral dose and subacute dietary toxicity endpoints to the overall conclusions of acute avian risk. The analysis indicated that, in most cases, the subacute dietary results had little impact on risk conclusions arrived upon by use of acute oral data alone. This finding is expected to reduce the number of animals tested by a total of 60 birds per test, for a total projected animal savings of over 700 animals per year based on a typical number of new chemicals registered.

## Policies and Guidance for Implementation of Alternative Methods

To encourage adoption and use of NAMs, the 2018 ICCVAM Strategic Roadmap (https://ntp.niehs.nih.gov/go/natl-strategy) called on agencies to provide clear guidance on use and acceptance of data from these approaches. During 2020 and 2021, agencies issued guidance for use of NAMs in the areas of testing for skin sensitization, carcinogenicity, and developmental and reproductive toxicity, as well as for testing of medical devices, vaccines, cancer drugs, pesticides, and consumer products.

### Measuring progress toward implementation of alternative methods in toxicity testing

Tags: ICCVAM, CPSC, DoD, DOI, DOT, EPA, FDA, NIEHS, NIH, USDA, metrics

In September 2019, the U.S. Government Accountability Office issued “Animal Use in Research: Federal Agencies Should Assess and Report on Their Efforts to Develop and Promote Alternatives (https://www.gao.gov/assets/710/701635.pdf).” This report describes how the U.S. Department of Health and Human Services, USDA, and EPA ensure researchers consider the use of alternatives to animals and examines the steps the agencies have taken to facilitate the use of alternative research methods and to assess the effect of their efforts on animal use. The report recommended that ICCVAM establish a workgroup to develop metrics that ICCVAM member agencies could use to assess progress made toward reducing, refining, or replacing animal use in testing. Furthermore, the report recommended that such metrics be incorporated into ICCVAM Biennial Progress Reports. In response, ICCVAM established its Metrics Workgroup in early 2020. The workgroup included members from nine ICCVAM agencies. Its charge was to determine how agencies can best address the Government Accountability Office report’s recommendations within the context of the ICCVAM Authorization Act (https://ntp.niehs.nih.gov/iccvam/docs/about_docs/pl106545.pdf).

In March 2021, the ICCVAM Metrics Workgroup published “Measuring U.S. Federal Agency Progress Toward Implementation of Alternative Methods in Toxicity Testing (https://ntp.niehs.nih.gov/iccvam/docs/about_docs/iccvam-measuringprogress-feb2021-fd-508.pdf),” which describes its findings and recommendations. The workgroup’s key finding was that no one set of metrics can be used by all ICCVAM member agencies to assess progress toward reducing, refining, or replacing animal use in testing. The workgroup instead recommended that each agency develop its own metrics that are relevant and practical to their unique situation. This document describes the recommendations of the ICCVAM Metrics Workgroup along with references and other materials that can be used to follow federal agency progress in promoting the use of alternative toxicological methods.

In response to the Metrics Workgroup’s recommendations, ICCVAM agencies have developed webpages to inform their stakeholders about progress on adoption of alternatives and reduction of animal use. Links to those pages are available on the NTP website (https://ntp.niehs.nih.gov/go/903258). Activities to assess progress toward reducing, refining, or replacing animal use in testing are also described throughout this report (https://ntp.niehs.nih.gov/iccvamreport/2021/tags/?topic=Metrics).

### Characteristics to consider when selecting a positive control material for an in vitro assay

Tags: CPSC, NIEHS, NIST

The use of in vitro assays to inform decision-making requires robust and reproducible results across studies, laboratories, and time. Experiments using positive control materials are integral to demonstrating the extent to which a measurement system is performing as expected. A paper by CPSC, NIEHS, and NIST scientists and collaborators (Petersen et al. 2021) reviewed 10 characteristics that should be considered when selecting a positive control material for an in vitro assay. These include: (1) the biological mechanism of action, (2) ease of preparation, (3) chemical purity, (4) verifiable physical properties, (5) stability, (6) ability to generate responses spanning the dynamic range of the assay, (7) technical or biological interference, (8) commercial availability, (9) user toxicity, and (10) disposability. The paper presented examples and a case study of the monocyte activation test to demonstrate the application of these characteristics for identification and selection of potential positive control materials. Because specific positive control materials are often written into testing standards for in vitro assays, selection of the positive control material based on these characteristics can aid in ensuring the long-term relevance and usability of these standards.

### Draft guidance on carcinogenicity testing

Tags: FDA, carcinogenicity

In an October 2021 Federal Register notice (86 FR 54982 (https://www.federalregister.gov/d/2021-21692)), FDA announced draft guidance for industry, “S1B(R1) Addendum to S1B Testing for Carcinogenicity of Pharmaceuticals (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/s1br1-addendum-s1b-testing-carcinogenicity-pharmaceuticals).” The draft guidance expands the testing scheme for assessing human carcinogenic risk of small molecule pharmaceuticals. It introduces an integrative approach that provides specific weight-of-evidence criteria that inform whether a 2-year rat study adds value in completing a human carcinogenicity risk assessment. The draft guidance also adds a plasma exposure ratio-based approach for setting the high dose in the rasH2-Tg mouse model. FDA accepted comment on the draft guidance through December 2021.

### Adoption of OECD guideline on defined approaches for skin sensitization testing

Tags: EPA, FDA, NIEHS, skin sensitization, ICCVAM

In June 2021, OECD issued Guideline 497, Defined Approaches on Skin Sensitisation (https://www.oecd-ilibrary.org/environment/guideline-no-497-defined-approaches-on-skin-sensitisation_b92879a4-en). Drafted and sponsored by ICCVAM agency scientists and international partners, Guideline 497 is the first internationally harmonized guideline to describe a non-animal defined approach that can be used to replace an animal test to identify skin sensitizers. Validation against a curated set of human data indicates that this approach predicts human skin sensitization hazard better than the accepted animal test. NICEATM and ICCVAM are collaborating with stakeholder groups to convene events to raise awareness about the guideline and promote best practices for implementation of defined approaches to skin sensitization testing and assessment.

### Draft risk assessment for chlorothalonil

Tags: EPA, inhalation toxicity

In a May 2021 Federal Register notice (86 FR 27593 (https://www.federalregister.gov/d/2021-10715)), EPA announced availability of draft human health and/or ecological risk assessments for several pesticides. EPA accepted public comment on the risk assessments through September 2021.

One of the pesticides covered by this announcement was the fungicide chlorothalonil, which was the subject of a case study to use an in vitro model to develop an inhalation risk assessment. The case study will be published in an OECD guidance document (https://www.oecd.org/officialdocuments/publicdisplaydocumentpdf/?cote=env/cbc/mono(2022)31&doclanguage=en) in 2022. Data from the in vitro model were used in conjunction with human dosimetry modeling to evaluate human inhalation risk, which is included in the document “Chlorothalonil: Revised Human Health Draft Risk Assessment for Registration Review.” This and other documents relevant to the chlorothalonil evaluation are available in a docket on Regulations.gov (https://www.regulations.gov/docket/EPA-HQ-OPP-2011-0840/document).

### Proposed guidance for industry for Federal Hazardous Substances Act testing

Tags: CPSC

In a March 2021 Federal Register notice (86 FR 16704 (https://www.federalregister.gov/d/2021-06567)), CPSC requested comment on its “Proposed Guidance for Industry and Test Method Developers: CPSC Staff Evaluation of Alternative Test Methods and Integrated Testing Approaches and Data Generated from Such Methods to Support Federal Hazardous Substances Act (FHSA) Labeling Requirements.” CPSC has developed this guidance, building on its Animal Testing Policy (https://www.cpsc.gov/Business--Manufacturing/Testing-Certification/Recommended-Procedures-Regarding-the-CPSCs-Policy-on-Animal-Testing), to assist stakeholders in determining what test methods are deemed reliable for determining compliance with the labeling requirements under the Federal Hazardous Substances Act. This includes clarification of CPSC informational requirements and a process for evaluating NAMs and IATA. CPSC accepted comments on the draft guidance through June 2021 and will release the final guidance (https://www.regulations.gov/document/CPSC-2021-0006-0010) in 2022.

### EPA list of NAMs for TSCA information requirements

Tags: EPA, acute toxicity, carcinogenicity

A 2016 update of the Toxic Substances Control Act (TSCA) required EPA to issue a list of methods and approaches that do not use vertebrate animals (i.e., NAMs) to develop new data or information required under TSCA. In February 2021, EPA updated the list of NAMs (https://www.epa.gov/sites/production/files/2021-02/documents/nams_list_second_update_2-4-21_final.pdf) that the agency will consider for the purpose of satisfying information requirements under TSCA. Some updates reflected changes made to OECD test guidelines, while other updates considered guidance on acute systemic toxicity testing waivers issued by the EPA Office of Pesticide Programs and availability of a new expert system to predict carcinogenicity of organic chemicals, fibers, metals, and polymers.

The NAMs list is an element of EPA’s 2018 “Strategic Plan to Promote the Development and Implementation of Alternative Test Methods Within the TSCA Program.” Information about the NAMs list and the Strategic Plan is available on the EPA website (https://www.epa.gov/assessing-and-managing-chemicals-under-tsca/strategic-plan-reduce-use-vertebrate-animals-chemical).

### Draft risk assessment for isothiazolinones

Tags: ICCVAM, EPA, NIEHS, skin sensitization

In May 2020, EPA requested comment (85 FR 28944 (https://www.federalregister.gov/d/2020-10376)) on draft human health and ecological risk assessments (https://www.regulations.gov/docket/EPA-HQ-OPP-2014-0159/document) for a group of antimicrobial chemicals known as isothiazolinones. EPA accepted comments on the draft risk assessments through November 2020.

Isothiazolinones are used in a variety of products including plastics, household cleaners, and laundry detergents. They frequently cause skin sensitization. EPA requested comment on the use of an in vitro and artificial neural network-based defined approach instead of using laboratory animal data to evaluate skin sensitization risks for products containing isothiazolinones. This is the first consideration of this type of defined approach in regulatory risk assessment.

The draft risk assessments rely heavily on work done by NIEHS and ICCVAM. The in vitro testing was conducted by the Toxicology Branch (https://ntp.niehs.nih.gov/whatwestudy/testpgm/immtox/index.html) of DNTP. NICEATM analyzed the in vitro data and ran the artificial neural network-based defined approach to provide quantitative potency predictions used to determine PODs. The ICCVAM Skin Sensitization Expert Group reviewed the DNTP testing report and the NICEATM analyses before data were provided to EPA for development of the risk assessments.

### Guidance on nonclinical evaluation of immunotoxic potential

Tags: FDA, skin sensitization, biologics

In February 2020, FDA issued draft guidance on “Nonclinical Safety Evaluation of the Immunotoxic Potential of Drugs and Biologics (https://www.fda.gov/media/135312/download).” This guidance supplements previously issued recommendations on nonclinical evaluations of immunotoxic potential and is intended to assist sponsors in such evaluations. The guidance includes several specific recommendations on assessing potential for dermal sensitization:

- FDA no longer recommends that sponsors conduct the murine local lymph node assay to assess the sensitization potential of topical drug products due to the limitations of the assay.
- As an alternative screen for skin sensitization for individual chemicals, FDA will consider a battery of in silico, in chemico, and in vitro studies that have been shown to adequately predict human skin sensitization with an accuracy similar to existing in vivo methods.

### Guidance on in vitro drug interaction studies

Tags: FDA

In January 2020, FDA published “In Vitro Drug Interaction Studies – Cytochrome P450 Enzyme- and Transporter-mediated Drug Interactions Guidance for Industry (https://www.fda.gov/regulatory-information/search-fda-guidance-documents/vitro-drug-interaction-studies-cytochrome-p450-enzyme-and-transporter-mediated-drug-interactions).” This guidance is intended to help drug developers plan and evaluate studies to determine the drug-drug interaction potential of an investigational drug product. It focuses on in vitro approaches to evaluate the interaction potential between investigational drugs with cytochrome P450 enzymes and transporters, as well as how in vitro results can inform future clinical drug-drug interaction studies. The appendices of this guidance include factors to consider when choosing in vitro experimental systems, key issues regarding in vitro experimental conditions, and more detailed explanations regarding model-based drug-drug interaction prediction strategies.

### Guidance on reproductive and developmental toxicity studies for human pharmaceuticals

Tags: FDA, developmental toxicity

In May 2021, FDA published “S5(R3) Detection of Reproductive and Developmental Toxicity for Human Pharmaceuticals - Guidance for Industry (https://www.fda.gov/media/148475/download)” This guidance is intended to help drug developers plan and evaluate nonclinical developmental and reproductive toxicity studies necessary to support human clinical trials and marketing authorization for pharmaceuticals. The 2021 revisions to this guidance describe testing strategies utilizing alternative assays for the assessment of malformations and embryofetal lethality. The guidance also provides basic principles that will assist in the development, qualification, and potential regulatory use of alternative assays for evaluating adverse effects on embryofetal development.

### Amendment of Hazardous Materials Regulations to consider in vitro methods for classification of corrosives

Tags: DOT

In August 2021, the Pipeline and Hazardous Materials Safety Administration (PHMSA) of the U.S. Department of Transportation published a Notice of Proposed Rulemaking (86 FR 43844 (https://www.federalregister.gov/documents/2021/08/10/2021-15425/hazardous-materials-harmonization-with-international-standards)) to amend certain sections of the Hazardous Materials Regulations (49 CFR parts 171 to 180 (https://www.ecfr.gov/current/title-49/part-171)). The purpose of the amendments is to maintain alignment with international regulations and standards relevant to the transportation of hazardous materials. The proposed amendments build on international collaborations of PHMSA with the United Nations to update the classification criteria for Class 8 (corrosive) substances to include in vitro non-animal test methods. The rulemaking incorporates the 2016 version of OECD Test No. 431, In Vitro Skin Corrosion: Reconstructed Human Epidermis (RHE) Test Method, used to assign a packing group to Class 8 materials. The rulemaking also provides an opportunity to assign certain Class 8 materials to a more conservative packing group in lieu of additional in vivo testing, reducing the need for animal testing to transport corrosive materials safely. The public comment period for the proposed rulemaking ended in October 2021 and the final rule is now being reviewed.