# Confidence

Establishing confidence in new testing methods requires engagement by both federal agencies and stakeholders. To support this goal, ICCVAM agencies evaluate the suitability of new methods for specific purposes and facilitate communication and education about new methods.

## Assay Application

ICCVAM and its member agencies conduct, support, and evaluate studies investigating the suitability of new laboratory methods for specific purposes. Methods evaluated during 2020 and 2021 addressed endpoints including inhalation toxicity, skin sensitization, eye irritation, and developmental toxicity.

### Electrophilic allergen screening assay validation study

Tags: ICCVAM, skin sensitization, CPSC, DoD, FDA, NIST, NIOSH

Binding of a chemical to skin proteins is the first step in the development of allergic contact dermatitis. The electrophilic allergen screening assay is a chemical assay that measures light absorbance or a fluorescent signal in proportion to a chemical’s tendency to bind to proteins.

The electrophilic allergen screening assay, developed by scientists at the National Institute for Occupational Safety and Health, was nominated to ICCVAM to evaluate its usefulness for identifying potential skin sensitizers. Five ICCVAM member agencies are participating in an ongoing validation study of the assay. Testing of 10 chemicals during 2018 showed that the method has sufficiently good reproducibility and accuracy rates to support further evaluation. In 2019, scientists at CPSC and the National Institute of Standards and Technology (NIST) modified the assay to a 96-well format to increase throughput and accessibility of the assay; details of this process are described in an abstract (Gordon et al.) presented at the SOT 2020 annual meeting. Testing of 20 chemicals will be completed during 2022 using the 96-well assay.

### OptiSafe validation study

Tags: ICCVAM, NIEHS, eye irritation, acute toxicity

NICEATM coordinated a multi-laboratory validation study to determine the reliability and relevance of the OptiSafe test method. In this method, a test substance is applied to a semi-permeable membrane to assess the substance’s potential to cause eye irritation.

The study was completed in 2018 and a report on the study has been published (Choksi et al. 2020). The study demonstrated that the OptiSafe method is useful for identifying non-surfactant substances that do not require classification for eye irritation and thus can reduce the use of animals for this type of testing.

### Developing a defined approach for eye irritation testing

Tags: EPA, NIEHS, eye irritation, IATA, mixtures toxicity

NICEATM, PETA Science Consortium International e.V., EPA, and CropLife America member companies are collaborating to develop an in vitro defined approach for hazard classification of eye irritation potential of agrochemical formulations. A three-phased prospective evaluation was designed to (1) assess the applicability of seven in vitro eye irritation/corrosion protocols to agrochemical formulations and (2) develop a defined approach for agrochemical formulations testing for prediction of U.S. and international irritancy classifications. Sixteen formulations were tested in the bovine corneal opacity and permeability, neutral red release, isolated chicken eye, EpiOcular, and porcine cornea reversibility test methods. Results were compared to the hazard classification assigned based on the in vivo rabbit test (Choksi et al. 2021 (https://doi.org/10.22427/NTP-NICEATM-1)). For each test method, at least one formulation was discordant with the in vivo rabbit classification, but none of the methods yielded discordant results for all tested formulations. Initial results indicate that certain test method combinations may be used to predict in vivo outcomes. Additional analyses will focus on physicochemical properties and composition of tested formulations to determine if there are any common features that impact in vitro test method performance. Analysis results were presented in a poster (Choksi et al. (https://ntp.niehs.nih.gov/iccvam/meetings/11wc/choksi-wc11_508.pdf)) at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences (https://ntp.niehs.nih.gov/whatwestudy/niceatm/publications-and-presentations/presentations-at-scientific-meetings/wc11/index.html). These data will be considered in the context of a recent review of eye anatomy and mechanisms of chemically induced eye irritation in humans and other species (Clippinger et al. 2021), which supported reduced reliance on comparisons to rabbit data to show the validity of other methods in favor of a greater focus on human relevance and assay reliability.

### Interlaboratory study to examine effects of key protocol elements for zebrafish developmental toxicity studies

Tags: NIEHS, developmental toxicity

To enable broader adoption of zebrafish for toxicological screening, NTP established the Systematic Evaluation of the Application of Zebrafish in Toxicology (https://ntp.niehs.nih.gov/go/seazit) (SEAZIT) program.

An initial information-gathering phase of the SEAZIT program identified a need for an interlaboratory study to examine the effects of variation in key protocol elements in developmental toxicity studies. The study was designed to determine the effect of chorion removal and exposure media renewal on study outcomes. Participating laboratories will use in-house protocols to test a defined chemical set while varying these two protocol elements. The chemical set, which was designed to provide overlap with other NTP studies, includes chemicals with a range of physicochemical properties and developmental effects. Many of the chemicals have in vivo reference data available from rodent and other zebrafish studies. The interlaboratory study also includes a pilot study of chemical kinetics in support of future studies of ADME in zebrafish. Dose range-finding experiments study began in 2019, although progress over the last 2 years has been delayed due to COVID-related laboratory closures.

In addition to advancing broader adoption of zebrafish for toxicological screening, SEAZIT is also supporting development of best practices for data analysis. To this end, the data generated in this study will be made publicly available, so that all study data may be used by investigators to estimate consensus toxicity values for each chemical.

### Testing to expand the applicability domain of three in vitro skin sensitization assays

Tags: NIEHS, CPSC, EPA, FDA, skin sensitization, IATA, mixtures toxicity

In 2021, OECD issued Guideline 497, Defined Approaches on Skin Sensitisation (https://www.oecd-ilibrary.org/environment/guideline-no-497-defined-approaches-on-skin-sensitisation_b92879a4-en). Drafted and sponsored by ICCVAM agency scientists and international partners, Guideline 497 is the first internationally harmonized guideline to describe a non-animal approach that can be used to replace an animal test to identify skin sensitizers.

To assess and expand the potential applicability of these defined approaches and those accepted by EPA (https://www.epa.gov/pesticides/epa-releases-draft-policy-reduce-animal-testing-skin-sensitization) to a broader range of chemical types, ICCVAM agencies nominated more than 200 chemicals for additional testing in the direct peptide reactivity assay, the KeratinoSens assay, and the human cell line activation test. Chemicals tested included pesticide ingredients and formulations, industrial chemicals, and personal care product ingredients. NTP completed this testing in 2020; reports are being prepared for publication in 2022. A poster describing performance of these test methods individually and in the defined approach for testing of 27 agrochemical formulations (Strickland et al. (https://ntp.niehs.nih.gov/iccvam/meetings/11wc/strickland-wc11_508.pdf)) was presented at the 11th World Congress on Alternatives and Animal Use in the Life Sciences (https://ntp.niehs.nih.gov/whatwestudy/niceatm/publications-and-presentations/presentations-at-scientific-meetings/wc11/index.html).

### Application of the monocyte activation test for medical device pyrogen testing

Tags: FDA, NIEHS

Pyrogens are substances that can produce fever when present as contaminants in a drug or medical device. Most pyrogens are biological substances derived from bacteria, fungi, and viruses; material-mediated pyrogens, while less common, may also be present. Drugs for injection and medical device products for implantation or other systemic exposure should meet pyrogen limit specifications before they are marketed.

Animal-based pyrogen tests are often conducted to investigate the presence of pyrogens. Non-animal monocyte activation tests (MAT) are widely available but infrequently used for pyrogen testing. To review MAT and discuss ongoing challenges to its widespread implementation for medical device testing, NICEATM and PETA Science Consortium International e.V. co-organized a September 2018 workshop. A workshop report has been published in ALTEX (Brown et al. 2021).

Workshop participants explored how the FDA Medical Device Development Tools Program could be used to qualify MAT as a standalone pyrogen test for specific medical device contexts of use. Attendees discussed practical aspects of pyrogen testing and the evidence needed to support qualification of MAT as a replacement for animal-based pyrogen tests. There was general agreement that MAT could be qualified as acceptable for batch-release testing for microbial-based pyrogens. However, additional studies were recommended to demonstrate its ability to detect known material-mediated pyrogens. This testing would determine whether the assay can be used for both biocompatibility and sterility or if other information on material-mediated pyrogens would be needed to address biocompatibility. Participants also discussed information gaps on material-mediated pyrogens, potential test controls, and other challenges and opportunities for implementing the use of MAT as a comprehensive pyrogen test.

### Human-relevant approaches to assess eye corrosion/irritation potential

Tags: NIEHS, EPA, eye irritation, IATA, mixtures toxicity

Although multiple internationally harmonized test guidelines describe in vitro and ex vivo eye irritation and corrosion test methods for regulatory use, these methods have not been widely adopted for testing agrochemical formulations due to a lack of concordance with parallel results from the rabbit eye test. The inherent variability of the rabbit test, differences in the anatomy of the rabbit and human eyes, and differences in modeling exposures in rabbit eyes relative to human eyes contribute to this lack of concordance. Because the regulatory purpose for these tests is protection of human health, there is a need for a testing approach based on human biology. A paper coauthored by EPA and NICEATM (Clippinger et al. 2021) reviews the available in vivo, in vitro, and ex vivo test methods with respect to their relevance to human ocular anatomy, anticipated exposure scenarios, and the mechanisms of eye irritation/corrosion in humans. Consideration of the mechanisms of eye irritation and the strengths and limitations of the in vivo, in vitro, and ex vivo test methods show that the in vitro and ex vivo methods are as or more reflective of human biology and less variable than the currently used rabbit approach. The paper suggests approaches to further optimize the most promising methods to distinguish between severe (corrosive), moderate, mild, and non-irritants and provide information about the reversibility of effects. It also considers the utility of including additional information such as physicochemical properties in a hazard assessment, consistent with accepted guidance (OECD 2019 (https://www.oecd.org/officialdocuments/publicdisplaydocumentpdf/?cote=ENV-JM-MONO(2017)15/REV1%20&doclanguage=en)) on integrated approaches to testing and assessment (IATA) for potential eye irritation.

### Selecting a minimal set of androgen receptor assays for screening chemicals

Tags: EPA, NIEHS, endocrine disruptors, AOP, IATA

Screening certain environmental chemicals for their ability to interact with endocrine targets, including the androgen receptor, is an important global concern. EPA and NICEATM previously developed a model using a battery of 11 in vitro androgen receptor assays to predict in vivo androgen receptor activity (Kleinstreuer et al. 2017 (http://pubs.acs.org/doi/abs/10.1021/acs.chemrestox.6b00347)). Follow-up work completed in 2020 (Judson et al. 2020) revised the modeling approach to incorporate data from newly available assays and demonstrate that subsets of assays can provide close to the same level of predictivity. These subset models were evaluated against the full 11-assay model using 1,820 chemicals, as well as in vitro and in vivo reference chemicals from the literature. Agonist batteries of as few as six assays and antagonist batteries of as few as five assays can yield balanced accuracies of 95% or better relative to the full model. Balanced accuracy of the subset batteries for predicting reference chemicals was 100%. The paper also outlines an approach for researchers to develop their own subset batteries to accurately detect androgen receptor activity using assays that map to the pathway of key molecular and cellular events involved in chemical-mediated androgen receptor activation and transcriptional activity. This work indicates that in vitro bioactivity and in silico predictions mapping to the androgen receptor pathway could be used in an IATA for identifying chemicals that interact directly with the mammalian androgen receptors.

### An evaluation framework for NAMs for human health safety assessment

Tags: FDA, NIEHS

Increased interest in using NAMs for safety assessment has resulted in an explosion of initiatives by numerous organizations. For the most part, these have been carried out independently and are not coordinated in any meaningful way. To help remedy this situation, a multistakeholder group of industry, academic, and regulatory experts including FDA and NIEHS scientists developed a framework that presents a consistent set of criteria, universal across initiatives, to evaluate a NAM’s fit-for-purpose (Parish et al. 2020). This framework will provide a structure to collect relevant, confidence-building information that will accelerate, facilitate, and encourage development of new NAMs for use within the appropriate regulatory contexts. In addition, this framework provides a systematic approach to evaluate currently available NAMs and determine their suitability for potential regulatory application. This three-step evaluation framework, along with the demonstrated application with case studies, will help build confidence in the scientific understanding of these methods and their value for chemical assessment and regulatory decision-making.

### Agencies partner with NASA to provide support for MPS research

Tags: FDA, NCI, NIH, MPS

In May 2021, the National Aeronautics and Space Administration (NASA) announced a multiagency initiative, “Extended Longevity of 3D Tissues and Microphysiological Systems for Modeling of Acute and Chronic Exposures to Stressors (http://spaceref.com/news/viewsr.html?pid=54832).” The initiative is focused on adapting existing 3D tissues and MPS to extend their longevity to at least 6 months. Among the sponsors of the initiative are several ICCVAM agencies: National Institutes of Health (NIH; NCATS and National Institute of Allergy and Infectious Diseases), NCI, and FDA. Proposals for projects to be funded under the initiative were accepted through September 2021, with awardees announced in March 2022 (https://science.nasa.gov/science-news/biological-physical/4-agencies-select-8-research-projects-to-extend-longevity-of-3d-tissue-chips-to-6-months).

### FDA pilot program to support novel approaches to drug development

Tags: FDA, MPS

In November 2020, FDA announced establishment of the Innovative Science and Technology Approaches for New Drugs (https://www.fda.gov/drugs/drug-development-tool-ddt-qualification-programs/innovative-science-and-technology-approaches-new-drugs-istand-pilot-program) pilot program. This program is designed to encourage innovation of drug development tools that are out of scope for existing qualification programs but may still be useful for drug development. Drug development tools are methods, materials, or measures that have the potential to facilitate drug development. Approaches that could be considered under the pilot program include using MPS to assess safety or efficacy questions; developing novel nonclinical pharmacology or toxicology assays; or using artificial intelligence-based algorithms to evaluate patients, develop novel endpoints, or inform study design.

### Optimization and validation of an in vitro botulinum neurotoxin assay

Tags: DOI, NIEHS, biologics, ecotoxicity, neurotoxicity

Tests to detect and measure botulinum neurotoxin are required by multiple federal agencies for a variety of purposes, such as detecting toxin in possibly contaminated food or wildlife. Currently, the standard test for these endpoints is a mouse lethality assay that can use large numbers of animals. NIEHS supported the optimization and validation of enzyme-linked immunosorbent assays (ELISAs) that replace animal-based methods for diagnosing suspected avian botulism samples. Methods were developed for determining the presence or absence of botulinum neurotoxin serotypes C-D (chimeric toxin) and E in field-collected samples from a wide range of bird species. There was good correlation between botulinum intoxication diagnoses and the ELISAs in the optimization phases, but occurrences of false positives and false negatives in specific scenarios were identified as opportunities for improvement. To address these potentially confounding factors, the USGS National Wildlife Health Center (DOI) is accumulating data and setting sample quality standards. Progress on testing these samples in the ELISA assay has been hampered over the last 2 years due to the pandemic but will progress in 2022 as conditions permit.

### Application of defined approaches to evaluating skin sensitization potential of agrochemicals

Tags: NIEHS, skin sensitization, IATA, mixtures toxicity

Skin sensitization testing is a regulatory requirement for safety evaluations of pesticides in multiple countries. Globally harmonized test guidelines that include in chemico and in vitro methods reduce animal use, but no single assay is recommended as a complete replacement for animal tests. Defined approaches that integrate data from multiple non-animal methods are internationally accepted, specifically via OECD Guideline 497 (https://www.oecd-ilibrary.org/environment/guideline-no-497-defined-approaches-on-skin-sensitisation_b92879a4-en). However, these defined approaches were evaluated with mono-constituent substances, which may limit their applicability to multi-constituent substances such as pesticides. An analysis by NIEHS scientists and collaborators evaluated rule-based defined approaches for hazard and/or potency categorization of skin sensitization for agrochemical formulations. The data set for the analysis included 27 formulations, each tested using the direct peptide reactivity assay, the KeratinoSens™ assay, and the human cell line activation test. The KeratinoSens assay had the highest performance for predicting in vivo hazard outcomes and performed better than any of the defined approaches. These results were presented in a poster (Strickland et al. (https://ntp.niehs.nih.gov/iccvam/meetings/ascct-2021/strickland_dass_ascct2021_508.pdf)) at the 2021 annual meeting of the American Society for Cellular and Computational Toxicology (https://ntp.niehs.nih.gov/go/ascct-2021). The analysis demonstrates that non-animal test methods have utility for evaluating the skin sensitization potential of agrochemical formulations. Further investigation will be required to determine whether defined approaches can outperform individual assays for predicting in vivo sensitization hazard of pesticide formulations in general.

### In vitro strategy for screening environmental chemicals and mixtures

Tags: DOI, ecotoxicity, mixtures toxicity

USGS (DOI) is collaborating with McGill University and Environment and Climate Change Canada to evaluate and validate the use of an avian embryo early life stage test in conjunction with transcriptomic assessment using the avian EcoToxChip (Farhat et al. 2019 (https://setac.onlinelibrary.wiley.com/doi/full/10.1002/etc.4582)) for screening environmental chemicals and mixtures. The early life stage test is a more biologically realistic alternative to cell-based in vitro testing methods because metabolism and multi-organ effects can be studied. Other advantages of the early life stage protocol are its low cost and rapidity, its reduced animal usage, and its ability to be applied to non-model or wildlife species to improve cross-species toxicity assessments. The avian EcoToxChip, developed initially for Japanese quail, is a targeted quantitative polymerase chain reaction array of about 360 genes. It includes genes representing about 20 biological pathways of regulatory relevance, including immune and endocrine systems and xenobiotic metabolism. In tandem with its partnered data evaluation tool (https://www.ecotoxxplorer.ca/), this focused transcriptomic approach will permit more rapid and less expensive characterization, prioritization, and management of environmental chemicals, reducing animal use.

### Use of cause-and-effect analysis to optimize reliability of in vitro inhalation toxicity assays

Tags: CPSC, NIST, inhalation toxicity

Human-relevant in vitro inhalation toxicology methods are increasingly being used to replace animal testing for research and regulatory purposes. However, these methods use a variety of biological test systems, exposure platforms and conditions, substances tested, and endpoints. These differences represent a major challenge for use of the methods in regulatory testing. Additionally, there is a need to systematically account for variability and maximize the reliability of these methods, especially methods that use cells cultured at an air–liquid interface. One tool that has been used to evaluate the robustness of in vitro test methods is cause-and-effect analysis, a conceptual approach to analyze key sources of potential variability in a test method. Identified sources of variability can then be evaluated using robustness testing and potentially incorporated into in-process control measurements in the assay protocol. A paper by CPSC and NIST scientists and collaborators (Petersen et al. 2021) describes how cause-and-effect analysis can be applied using a modular approach, based on the idea that shared components of different test methods have similar sources of variability even though other components may differ. Cause-and-effect analyses of different in vitro inhalation methods revealed a common set of recommended exposure systems and biological in-process control measurements. This approach, when applied in conjunction with Good Laboratory Practice criteria, should help improve the inter- and intralaboratory agreement of in vitro inhalation test results, leading to increased confidence in these methods for regulatory and research purposes.

### Quantitative analysis of in vitro assay data to rank mutagenic potency of cigarette products

Tags: FDA, carcinogenicity, inhalation toxicity, mixtures toxicity, genotoxicity

Short-term in vitro genotoxicity assays are useful tools to assess whether new and emerging tobacco products potentially have reduced toxicity. Scientists at the FDA Center for Tobacco Products and the FDA National Center for Toxicological Research used quantitative analysis of data from two types of in vitro tests to rank mutagenic potency of cigarette whole-smoke solutions.

Meng et al. (2021) (https://pubmed.ncbi.nlm.nih.gov/34131742/) used the bacterial reverse mutation (Ames) test to analyze whole-smoke solution samples generated from two commercial cigarette brands under different smoking machine regimens. Benchmark dose modeling analysis was used to rank the mutagenic potency of the products. The quantitative approaches resulted in a similar rank order of mutagenic potency for the Ames test for both frameshift mutations and base-pair substitution. Under the conditions of this study, these results indicate that quantitative analysis of the Ames test data can discriminate between the mutagenic potencies of whole-smoke solution samples on the basis of smoking machine regimen and differences in smoke chemistry.

Mittelstaedt et al. (2021) (https://pubmed.ncbi.nlm.nih.gov/33985695/) evaluated dose-response modeling of in vitro micronucleus test data to determine if this test can discriminate among different tobacco products. Micronucleus responses were generated in mouse lymphoma and human lymphoblastoid cells from a series of whole-smoke solutions expected to have different levels of genotoxicity based on differences in their machine-generated smoke constituents. Eight whole-smoke solutions were prepared by machine-smoking different numbers of two commercial cigarettes under two different smoking machine regimens and tested in the two cell lines with and without rat liver S9 activation. The S9-mediated dose-response data were evaluated with PROAST software (developed by the Netherlands National Institute for Public Health and the Environment) and benchmark doses and upper and lower confidence intervals generated. The response differed based on the number and type of cigarettes smoked and smoking machine regimen. Responses produced in mouse lymphoma cells generally were greater than in the human lymphoblastoid cells, but the ability of the two cell types to differentiate between whole-smoke solutions was similar. The results indicate that benchmark dose potency ranking is useful for differentiating between in vitro micronucleus test responses.

### Chemical and in vitro bioactivity analysis of cigarillos

Tags: FDA, carcinogenicity, inhalation toxicity, mixtures toxicity, genotoxicity

There has been limited toxicity testing of cigarillos, including comparisons to cigarettes. A study by scientists at the FDA Center for Tobacco Products and collaborators (Crosby et al. 2021 (https://academic.oup.com/toxsci/article-abstract/180/1/122/5917030)) compared the smoke chemistry and the cytotoxic and genotoxic potential of 10 conventional cigarettes and 10 cigarillos based on the greatest market share. Tobacco-specific nitrosamines, carbonyls, and polycyclic aromatic hydrocarbons were measured using gas chromatography-mass spectrometry. Bioactivity of total particulate matter smoke extracts was evaluated using several in vitro assays. Cytotoxicity was assessed in continuously cultured human bronchial epithelial cell lines using the neutral red uptake assay. Genotoxic potential was assessed using the micronucleus (continuously cultured human lung adenocarcinoma cell line), Ames, and thymidine kinase assays. The study found that the tested U.S.-marketed cigarillos have greater tobacco constituent levels, cytotoxicity, and genotoxicity than the compared cigarettes. These findings are important for understanding the human health toxicity from the use of cigarillos relative to cigarettes and for building upon knowledge regarding harm from cigarillos to inform risk mitigation strategies.

### Evaluation of farnesoid X receptor (FXR)-active chemicals identified from Tox21 screening

Tags: NIEHS, Tox21

One of the primary goals of Tox21 is using in vitro HTS assays to prioritize toxicity evaluations for large numbers of chemicals in commercial use for which little or no toxicity data are available. Chemicals that can disrupt nuclear receptor signaling are a particular area of interest for Tox21 because such activity can have profound biological impacts. The farnesoid X receptor (FXR) is a nuclear receptor that can affect bile acid homeostasis, glucose metabolism, lipid homeostasis and hepatic regeneration. NIEHS scientists and collaborators evaluated FXR agonists and antagonists identified through Tox21 screening using in vitro cell-based assays, in silico modeling approaches, and in vivo assessments using a fish model. These studies demonstrated the molecular complexity of FXR–ligand interactions and confirmed the ability of diverse ligands to modulate FXR, facilitate differential coregulator recruitment, and activate or repress receptor-mediated transcription. A paper describing these studies will be published in 2022.

### Optimization and prequalification of a splenocyte-based assay for potency testing of vaccines

Tags: NIEHS, biologics

Potency assays for vaccines are often limited to animal-based methods in which animals are immunized, challenged with the disease vector, and evaluated for symptoms or mortality. NIEHS has supported the evaluation of a novel relative potency assay that measures immunological response in vitro. This method uses splenocytes from vaccine-immunized animals to determine the ability of increasing doses of a vaccine to elicit a reactivation response in vitro. Therefore, this method has potential to both reduce and refine animal use for vaccine potency testing. The test method developer has also established a cryopreservation procedure to allow long-term storage of splenocytes. The goals of this study are to (1) determine whether a splenocyte-based assay can reliably determine the relative potency of a test sample, and (2) demonstrate that cryopreserved cells can be used in the proposed potency method.

### Use of fish embryo toxicity tests for prioritizing testing of environmental contaminants

Tags: DOI, cardiotoxicity, developmental toxicity, ecotoxicity

As part of ongoing assessments of wildlife health, DOI is investigating potential cardiovascular effects on fish from pesticides and pharmaceuticals frequently detected in surface waters and fish tissues. The USGS Columbia Environmental Research Center conducts high-content screening of compounds to formulate hypotheses and prioritize compounds for further toxicity testing. This approach reduces animal use, test compound needed, and waste by utilizing pre-feeding fish embryos in a microtiter plate format. This approach is also being used to better characterize toxicity of polycyclic aromatic hydrocarbons (PAHs) and oxygenated PAHs from a subsurface oil spill by assaying groundwater samples from different trophic levels. These assays can provide evidence to justify larger-scale studies to determine actual risk versus perceived risk of contaminants.

The USGS Center’s current high-content screening assay is a developmental cardiotoxicity assay that assesses total body length, pericardial area, intersegmental vessel area, circulation, and heart rate after a 72-hour exposure to a test substance. This array of endpoints allows for a targeted assessment of toxicity. In addition to an LC50 estimate, the assay provides a rapid approach to inform on mode of action, allowing formation of hypotheses on sublethal impacts of contaminants. Data derived from these studies on acute toxicity and mode of action for pesticides, pharmaceuticals, PAHs, and oxygenated PAHs will support a better understanding of potential effects on wildlife species.

### Alternative approaches to evaluating bioactivity in surface waters

Tags: DOI, carcinogenicity, ecotoxicity, endocrine disruptors, genotoxicity

Chemical contaminants are introduced to environmental waters via many sources, and many of these contaminants have the potential to adversely affect organisms living in these waters. Recognized adverse effects include the induction of cancer via genotoxic mechanisms, endocrine disruption via the derailment of normal hormone signaling pathways, and outright toxicity leading to disease or death. Over the past decade, USGS scientists (DOI) have established or adapted water collection, extraction, and in vitro screening assays to evaluate the bioactivity of surface water samples. These approaches circumvent the need to utilize vertebrates and minimize endpoint variability in bioactivity measures. Data from these assays are incorporated into predictive modeling analyses to identify land uses associated with predicted biological disruption. They are also applied to responsibly inform site selection for comprehensive environmental sampling. Notably, it has been found that these approaches are better predictors of the impact of various land use scenarios on wildlife health than sentinel vertebrates sampled at the same locations. During 2020-2021, these assays were applied to augment USGS and other collaborator data sets collected from environmental surface and well waters collected in the eastern and midwestern United States.

### Integrated selection and screening process for potential fish toxicants

Tags: DOI, acute toxicity, ecotoxicity, QSAR

Fisheries managers use pesticides, specifically referred to as management chemicals, to control invasive and undesirable fish species. Effective management chemicals should show heightened toxicity to target invasive or undesirable species while posing a minimal hazard to native species. The USGS Upper Midwest Environmental Science Center (DOI) has developed a two-phase screening process to minimize the use of animal testing during the development of new management chemicals. Although in vivo testing continues to be utilized in the development of new management chemicals, the screening process minimizes the number of animal toxicity studies necessary during research and development.

In the first phase, an in silico analysis is conducted using ecotoxicity QSAR modeling that incorporates species sensitivity distributions and the EPA tool Sequence Alignment to Predict Across Species Susceptibility (SeqAPASS). The ecotoxicity modeling determines species-specific responses to chemical exposures using existing toxicity data and chemical physicochemical properties. These in silico assessment methods can be used to prioritize candidate compounds and estimate cytotoxicity. Models utilize more than 3,000 endpoints from over 600 taxa that are reported for more than 9,000 chemicals, and a publicly available interactive model prototype is in development.

In the second phase, promising chemical candidates identified by ecotoxicity modeling are tested using fish cell line cytotoxicity assays to examine target versus non-target species sensitivity. Cell lines developed from multiple tissue types (e.g., gill tissue) were established at the U.S. Fish and Wildlife Service Midwest Fishery Center; species represented include bluegill, fathead minnow, lake sturgeon, paddlefish, gizzard shad, silver carp, bighead carp, grass carp, and trout. Multiple species-specific chemical candidates have been identified and screened through cytotoxicity assays, with only the most promising candidates evaluated using in vivo toxicity studies.

### Activities of the Developmental Neurotoxicity Health Effects Innovation Program

Tags: NIEHS, developmental toxicity, neurotoxicity

Exposure to environmental chemicals is a contributing factor to the significant increase in prevalence of neurodevelopmental disorders in children. However, there is limited developmental neurotoxicity information on chemicals in use due to challenges and limitations with current in vivo guidelines. To address these challenges, an in vitro battery of promising NAMs was developed through an international collaboration (Crofton and Mundy 2021 (https://doi.org/10.2903/sp.efsa.2021.EN-6924)). An OECD guidance document with specific IATA case studies is being developed that informs on the application and interpretation of the testing battery, and will be published in 2022.

The Developmental Neurotoxicity Health Effects Innovation Program (DNT HEI) is a program within NIEHS DNTP that aims to generate and analyze screening-level information on chemicals using the in vitro battery. DNTP developed a unified data analysis pipeline to combine data from the individual assays in the in vitro battery (Behl et al 2019 (https://doi.org/10.1093/toxsci/kfy278)). In 2021, a set of 115 chemicals (Phase 1 chemicals (https://www.niehs.nih.gov/research/atniehs/assets/docs/developmental_neurotoxicity_screening_assay_chemical_list_508.pdf)) was selected and distributed for testing in the in vitro battery. Data have been received from most of the assay developers and are currently being analyzed by the DNT HEI, with results to be published in early 2023. A second set of chemicals has been selected by the DNT HEI based on nominations from various stakeholders.

In addition, DNTP led the development of a case study focused on organophosphorus flame retardants (https://www.oecd.org/officialdocuments/publicdisplaydocumentpdf/?cote=env/cbc/mono(2022)26&doclanguage=en) for use of a developmental neurotoxicity IATA to prioritize chemicals within a class of compounds. The case study will be included in the final OECD guidance document described above.

## Communication and Education

The 2018 ICCVAM Strategic Roadmap (https://ntp.niehs.nih.gov/go/natl-strategy) identified stakeholder engagement as critical to acceptance and use of new methods. To facilitate stakeholder engagement, ICCVAM and its member agencies organize public meetings and webinars. These events inform stakeholders about the availability and appropriate use of new methods and provide opportunities for stakeholders and agencies to discuss opportunities for test method development.

### ICCVAM Communities of Practice webinars

Tags: ICCVAM, ATSDR, EPA, NIEHS, antibodies, mixtures toxicity

In 2015, ICCVAM initiated a series of Communities of Practice webinars to provide opportunities for detailed presentations on a current topic relevant to alternative test method development.

- The sixth of these webinars, presented on Jan. 21, 2020, was titled Use of Animal-free Affinity Reagents (https://ntp.niehs.nih.gov/go/commprac-2020). In this webinar, Alejandra Solache, Ph.D., of Abcam presented an overview of production, use, and characteristics of monoclonal and polyclonal antibodies. Rebecca Clewell, Ph.D., of 21st Century Tox Consulting summarized a recent review by a working group of the Scientific Advisory Committee of the European Union Reference Laboratory for Alternatives to Animal Testing on the scientific validity and benefits of animal-free technologies to produce affinity reagents.
- The Jan. 26, 2021, Communities of Practice webinar focused on Non-animal Approaches for Mixtures Assessment (https://ntp.niehs.nih.gov/go/commprac-2021). In this event, three ICCVAM agency scientists described approaches being used to assess human risk of toxicity from mixtures. Cynthia Rider, Ph.D., NIEHS, discussed assessing safety of botanicals. Patricia Ruiz, Ph.D., Agency for Toxic Substances and Disease Registry (ATSDR), described computational approaches to predict toxicity of mixtures. Kristin Isaacs, Ph.D., EPA, presented a data mining approach that uses purchasing data to estimate exposure to consumer product ingredients.

### ICCVAM Public Forums

Tags: ICCVAM

Traditionally held in person, the ICCVAM public forum meetings in 2020 and 2021 were held virtually because of restrictions on public gatherings due to COVID-19. However, both meetings provided opportunities for public interaction with representatives from ICCVAM member agencies.

- View materials from the 2020 Public Forum (https://ntp.niehs.nih.gov/go/iccvamforum-2020)
- View materials from the 2021 Public Forum (https://ntp.niehs.nih.gov/go/iccvamforum-2021)

ICCVAM held its seventh public forum on May 21, 2020, which was viewed by about 400 individuals. Representatives of ICCVAM member agencies described work both to advance new approaches to safety testing of chemicals and medical products and to reduce the amount of testing required. Commenters at the forum commended the agencies’ progress and noted the importance of federal agencies taking leadership roles in reducing animal testing. In addition to government agencies, viewers represented pharmaceutical and chemical companies, animal welfare organizations, and test method developers.

The 2021 public forum was held on May 27 and attracted nearly 200 viewers. The program featured 13 presentations from nine of the 17 ICCVAM member agencies. Representatives described efforts to reduce animal use within their agencies and by their stakeholders, as well as research activities that advance new non-animal approaches. Stakeholders expressed particular interest in activities that advance alternatives to animal use in the context of regulatory requirements. Such activities were outlined by CPSC and two EPA offices. A request to the public for comments to be presented during the meeting produced a robust response, with nine commenters presenting during the meeting and an additional four written comments received.

### ICCVAM advisory committee meetings

Tags: ICCVAM, antibodies, ecotoxicity

The Scientific Advisory Committee on Alternative Toxicological Methods (SACATM) is a federally chartered advisory group that advises NICEATM, ICCVAM, and the Director of NIEHS about ICCVAM activities. Traditionally held in person, the 2020 and 2021 public meetings of SACATM were held virtually because of restrictions on gatherings due to COVID-19.

More than 200 people viewed or participated in the Sept. 2-3, 2020, SACATM meeting, making it one of the most broadly viewed SACATM meetings ever. Committee members praised advances in use of computational methods to reduce animal use for chemical safety testing. They suggested resources and approaches that could be developed to further advance these tools and identified testing areas where they could be applied. Committee members also encouraged ICCVAM member agencies to increase efforts to advance non-animal alternatives for identifying substances that could cause cancer or other chronic toxicity outcomes, and to promote strategies for reducing animal use for vaccine testing and antibody production.

About 160 people viewed the Sept. 28-29, 2021, SACATM meeting. This event focused on detailed discussion of two topics of current interest to ICCVAM: reducing or replacing animal use for ecotoxicity testing and new approaches to validation of new testing methods. The committee urged ICCVAM member agencies to support greater communication among regulators, regulated industry, and test method developers. ICCVAM members also were encouraged to engage groups focused on environmental justice and climate change.

### ICCVAM agency-sponsored workshops and webinars

Tags: EPA, FDA, NIEHS, NIH, acute toxicity, antibodies, biologics, carcinogenicity, COVID-19, eye irritation, IATA, inhalation toxicity, MPS, nanomaterials, neurotoxicity, skin sensitization

ICCVAM agencies convened workshops and webinars during 2020 and 2021, summarized in the table below, to foster collaboration and provide information about alternative testing methods. All meetings took place online.

Meeting Date | Sponsoring Agency (and partner organization) | Meeting Title (with link to page if available) | Meeting Summary
April 17, 2020 | NIEHS | NIEHS SBIR/STTR Town Hall: Development of New Approach Methodologies to Reduce Animal Use in Toxicity Testing (https://ntp.niehs.nih.gov/go/sbir-townhall-2020) | This online town hall meeting was presented to facilitate improved communication between method developers and end-users, providing an opportunity for assay developers to hear from ICCVAM stakeholders on the desired characteristics and requirements for NAMs.
May 14, 2020 | FDA | Artificial Intelligence for Regulatory Science Research (https://collaborationcqpub1.fda.gov/content/connect/c1/7/en/events/event/shared/default_template/event_landing.html?sco-id=199466948) | This presentation summarized current thinking and ongoing efforts at the FDA’s National Center for Toxicological Research in artificial intelligence, with examples from drug and food safety, natural language processing of regulatory documents, and biomarker discovery and development. The presentation also discussed guiding principles and best practices for applying artificial intelligence in regulatory science research.
Jan. 22, 2020-Nov. 3, 2021 | EPA (PETA Science Consortium International eV., Physicians Committee for Responsible Medicine) | Webinar Series on the Use of New Approach Methodologies (NAMs) in Risk Assessment (https://www.piscltd.org.uk/nam-webinars/) | These webinars discussed computational models for acute toxicity and carcinogenicity prediction, and skin sensitization and eye irritation testing. A September 2020 event presented a proposed NAM nomination form for Toxic Substances Control Act consideration. The series will continue in 2022.
Ongoing; initiated August 2020 | FDA | Alternative Methods Webinar Series (https://www.fda.gov/science-research/about-science-research-fda/fda-webinar-series-alternative-methods-showcasing-cutting-edge-technologies-disease-modeling) | This FDA internal webinar series, organized by the FDA Alternative Methods Working Group, provides test method developers with the opportunity to introduce their new technology to FDA and give individual FDA programs the option to contact them for further information.
Feb. 19, 2020-Dec. 1, 2021 | FDA (Society of Toxicology) | Colloquia on Emerging Toxicological Science: Challenges in Food and Ingredient Safety (https://www.toxicology.org/events/shm/fda/fda.asp) | Since 2014, the Society of Toxicology and the FDA Center for Food Safety and Applied Nutrition have presented colloquia on high-quality, cutting-edge, future-oriented toxicological science topics. Many of the colloquia focus on alternatives to animal use. The series is continuing into 2022.
July 23-Nov. 12, 2020 | NIEHS (PETA Science Consortium International eV., EURL ECVAM) | Antibody Webinar Series (https://www.thepsci.eu/antibody-webinars/) | Attendees learned about the applications and benefits of animal-free recombinant antibodies.
Sep. 15-17, 2020 | EPA | Use of NAMs to Derive Extrapolation Factors and Evaluate Developmental Neurotoxicity for Human Health Risk Assessment (https://www.epa.gov/sap/use-new-approach-methodologies-nams-derive-extrapolation-factors-and-evaluate-developmental) | This public meeting of the Federal Insecticide, Fungicide, and Rodenticide Scientific Advisory Panel considered and reviewed the use of NAMs to derive extrapolation factors and evaluate developmental neurotoxicity for human health risk assessment.
Sep. 30, 2020 | EPA, NIEHS (Health and Environmental Sciences Institute) | Opportunities and Challenges in Using the Kinetically Derived Maximum Dose Concept to Refine Risk Assessment (https://ntp.niehs.nih.gov/go/kmd-2020) | This symposium highlighted issues commonly raised in application of the kinetically derived maximum dose for design and interpretation of animal toxicity studies, and provided the background information needed to develop more consistent, transparent approaches to support broader application in risk assessment.
Oct. 19-20, 2020 | EPA | Conference on the State of Science on Development and Use of NAMs for Chemical Safety Testing (https://www.epa.gov/chemical-research/epa-conference-state-science-development-and-use-nams-chemical-safety-testing) | This was the second in a series of EPA conferences to highlight the state of the science on the development and use of NAMs for chemical safety testing. The next conference will be held in 2022.
May 19-June 2, 2021 | EPA (PETA Science Consortium International eV., Unilever, Syngenta) | Inhalation Toxicity Testing (https://www.thepsci.eu/inhalation-webinars/) | These three webinars focused on using in silico and in vitro approaches for next generation risk assessment of potential respiratory toxicants.
May 26-27, 2021 | FDA | FDA Science Forum (https://www.fda.gov/science-research/about-science-research-fda/fda-science-forum) | This event allowed the public to view scientific research and collaborative efforts of FDA scientists. Several topic areas focused on the application of big data and predictive toxicology to inform FDA decision-making and drive innovation.
June 24-Sep. 10, 2021 | NIEHS | Environmental Health Language Collaborative Webinars (https://www.niehs.nih.gov/research/programs/ehlc/) | These interactive events helped set the stage, begin discussions, and draft plans for how to make progress on the Collaborative’s goals.
Sep. 9, 2021 | NIH | Bioinformatics and Computational Biology Symposium (https://www.nihlibrary.nih.gov/services/bioinformatics-support/BioSymp21) | The program for this event included a keynote presentation on “Big data for health and disease” and presentations on DNA structure, proteomic tumor analysis, data integration to study COVID-19, single-cell sequencing, and genomics.
Sep. 21-Dec. 8, 2021 | NIEHS (Swiss Centre for Applied Human Toxicology, Swiss State Secretariat for Economic Affairs) | Current Concepts in Quantitative Risk Assessment for Skin Sensitization (https://ntp.niehs.nih.gov/go/ssqra-web) | This webinar series provides an overview of the current state of the science in this rapidly developing field. The webinars will continue in 2022 and are intended as background for a planned workshop on quantitative risk assessment of skin sensitizing pesticides.
Oct. 25, 2021 | EPA (Johns Hopkins University Center for Alternatives to Animal Testing) | Challenges and Opportunities for Overcoming Dog Use in Agrochemical Evaluation and Registration (https://www.youtube.com/watch?v=jjOHHpMJX8w&list=PLq3BABaYKtzndvLCmE2NT5DkB_sfCNIUs) | At this virtual workshop, presenters reviewed the role the 90-day dog study has played in the regulation of agrochemicals in both the U.S. and Europe during the past 20 years and what approaches may be employed to substantially reduce its use.

### Animal Welfare Information Center resources

Tags: USDA, metrics, ecotoxicity

The 1985 amendments to the Animal Welfare Act established the Animal Welfare Information Center (AWIC), an information service at the USDA National Agricultural Library (NAL). AWIC’s mission is to provide information pertinent to employee training that could prevent unintended duplication of animal experimentation and on improved research methods that could reduce or replace animal use and minimize pain and distress to animals.

AWIC provides information to the toxicology community on the NAL website related to the development and use of alternatives to toxicity testing, as well as information and guidelines on mandatory and regulatory testing set by various agencies. These web pages highlight peer-reviewed publications and other online resources that discuss ways to replace, reduce, and refine animal use in toxicity testing. For example, AWIC provides links and selected citations (updated in 2021) on 3Rs testing methods used in ecotoxicity testing (https://www.nal.usda.gov/legacy/awic/ecotoxicity-testing).

During 2020 and 2021, 256,208 people visited the AWIC website. These visits generated a total of 512,253 page views. AWIC also provides information on animal use alternatives through outlets such as presentations and posters, workshops, webinars, and conference exhibits. Through these outlets, AWIC presented to over 3,590 participants at 67 different outreach events in 2020 and 2021, collectively. At these outreach events, AWIC described best practices for searching and finding current literature on methods to reduce, refine, or replace animal use in testing and experimentation.

### FDA reports on progress in advancing alternatives

Tags: FDA, metrics, Tox21

In January 2021, FDA published “Advancing New Alternative Methodologies at FDA (https://www.fda.gov/media/144891/download),” which provided updates on activities to advance development of alternatives to animal use and their application to regulatory decision-making. The report was developed by the FDA Alternative Methods Working Group (https://www.fda.gov/alternativemethods) to highlight the progress made by FDA scientists in laying the groundwork to integrate alternatives to animal testing into FDA regulatory programs. The report described activities within eight FDA offices and centers, as well as FDA working groups and interagency partnerships such as ICCVAM and Tox21. The report also summarized FDA engagement to advance alternatives to animal testing in international venues such as OECD and the International Cooperation on Cosmetic Regulation.

### New agency webpages summarizing alternative methods activities

Tags: EPA, FDA, metrics

During 2020 and 2021, several ICCVAM agencies published new webpages summarizing activities to advance alternative methods.

- In May 2020, FDA published “Advancing Alternative Methods at FDA (https://www.fda.gov/science-research/about-science-research-fda/advancing-alternative-methods-fda),” which highlights activities of its Alternative Methods Working Group. The working group was established to facilitate interactions with global regulatory bodies interested in implementing alternative methods in toxicology. Additionally, the group examines opportunities and viable ways by which emerging methods and new technologies can support regulatory review of risk, safety, and efficacy of FDA-regulated products. Resources available from the page include links to relevant reports, publications, and FDA webpages and contact information for the working group.
- In October 2020, EPA published “Strategic Vision for Adopting New Approach Methodologies (https://www.epa.gov/pesticide-science-and-assessing-pesticide-risks/strategic-vision-adopting-new-approach),” which describes activities, partnerships, and goals of several EPA offices to reduce animal testing. Resources available from this page include links to EPA webpages that provide more details on activities within the EPA Offices of Pesticide Programs, Pollution Prevention and Toxics, Science and Policy Coordination, and Research & Development.
  A key resource within the EPA website is the webpage, “Adopting 21^st^ Century Science Methodologies – Metrics (https://www.epa.gov/pesticide-science-and-assessing-pesticide-risks/adopting-21st-century-science-methodologies-metrics).” This page includes data compiled by the Hazard and Science Policy Council, the Chemistry and Acute Toxicology Science Advisory Council, and other groups about how EPA activities and policies have reduced the number of animals used in testing and saved EPA and stakeholder resources.

## Computational Tools Applications

ICCVAM and its member agencies are exploring how computational approaches can be applied to reduce animal use for toxicity testing. These approaches have potential application for acute oral toxicity and eye irritation testing, and for predicting whether chemicals could cause cardiotoxicity, developmental toxicity, or neurotoxicity.

### CATMoS and additivity approaches to predict toxicity of mixtures

Tags: DoD, acute toxicity, oral toxicity, mixtures toxicity

The majority of existing toxicity data and tools to assess toxicity are for single compounds. However, humans are exposed to complex chemical mixtures in a variety of scenarios. Of particular interest to the U.S. Air Force are exposures to chemical mixtures experienced by airmen. Scientists at the U.S. Air Force Research Laboratory have developed a computational approach to help assess the acute oral toxicity of mixtures by using an additivity formula that estimates toxicity of a mixture based on the acute toxicity estimate of individual ingredients. Acute toxicity estimates for single chemicals were collected from existing databases or calculated using CATMoS (Chushak et al. 2021 (https://doi.org/10.1021/acs.chemrestox.0c00256)). The proposed approach was implemented in a standalone Python-based app that allows users to rapidly assess the acute toxicity for mixtures related to U.S. Air Force needs and to identify chemicals that can impact physiological performance of airmen.

### Analysis of the performance of the GHS Mixtures Equation to predict acute oral toxicity of formulations

Tags: EPA, NIEHS, acute toxicity, oral toxicity, mixtures toxicity

The majority of pesticide registration applications require product-specific acute toxicity data. Thus, an alternative to in vivo testing for this purpose could greatly reduce animal testing. However, predicting toxicity using NAMs is challenging for mixtures such as pesticides. The GHS Mixtures Equation estimates the acute toxicity of mixtures using the toxicities of mixture components. EPA and NIEHS scientists conducted a study (Hamm et al. 2021) to evaluate the concordance of hazard classifications predicted using the GHS Mixtures Equation with classifications based on in vivo test results. The results of the analysis suggested that the GHS Mixtures Equation can help predict the acute oral toxicity of mixtures, particularly those with lower toxicity.

### Use of IVIVE and data from a stem cell-based assay to predict developmental toxicity potential

Tags: FDA, NIEHS, developmental toxicity, IVIVE, stem cells

To support implementation of NAMs for regulatory decision-making on developmental toxicity, FDA and NIEHS scientists and collaborators evaluated the performance of the devTOX quickPredict assay for predicting lowest effect levels in rat developmental toxicity studies. Studies conducted during 2020 and 2021 focused on developmental toxicity potential of valproic acid and analogues (Chang et al. 2022 (https://doi.org/10.1002/bdr2.2019)) and 186 chemicals from the Tox21 program. Developmental toxicity potential (dTP) concentrations from the devTOX quickPredict assay were used as inputs to IVIVE analyses to estimate equivalent administered doses that would result in the maximum plasma concentrations equivalent to dTP concentrations. Results suggested that the devTOX quickPredict assay can quantitatively predict developmental toxicity potential at concentrations relevant to human exposure and in some cases may provide a more conservative hazard estimate than animal studies for use in risk assessment.

### In silico screening approaches for assessing cardiovascular safety

Tags: NIEHS, cardiotoxicity, endocrine disruptors, machine learning

Mounting evidence supports the contribution of environmental chemicals to cardiovascular disease burden. NIEHS scientists evaluated chemicals in the Tox21 chemical library for cardiotoxicity potential by focusing on HTS assays whose targets are associated with adverse events related to cardiovascular failure modes (Krishna et al. 2021). The objective of the evaluation was to develop new hypotheses around environmental chemicals of potential interest for adverse cardiovascular outcomes using Tox21 and ToxCast HTS data. Bioactivity signatures relevant to cardiotoxicity were identified for 40 targets measured in 314 assays and used to prioritize 1,138 Tox21 chemicals. The approach identified drugs with known cardiotoxic effects in a variety of use classes including estrogenic modulators, anti-arrhythmic drugs, and antipsychotic drugs like chlorpromazine. Several classes of environmental chemicals such as organotins, bisphenol-like chemicals, pesticides, and quaternary ammonium compounds demonstrated strong bioactivity against cardiovascular targets. Screening outcomes were added to existing data from literature studies using cultured heart cells, animals, or human epidemiological approaches to prioritize these chemicals for further testing.

A number of chemicals identified in the initial Tox21 screen were found to inhibit potassium channels important to cardiac rhythm regulation (Krishna et al. 2022 (https://doi.org/10.3390/biology11020209)). A set of molecular descriptors was applied to characterize these chemicals. Machine learning approaches were then applied to build robust statistical models that can predict the probability of any new chemical to cause cardiotoxicity via this mechanism.

### Application of CATMoS to predict acute mammalian toxicity for pesticide hazard and risk assessment

Tags: EPA, NIEHS, acute toxicity, oral toxicity

CATMoS is a set of predictive in silico models of acute oral systemic toxicity potential. The consensus model predictions are fully reproducible and demonstrate equivalent performance to in vivo data. This offers an opportunity for a potential replacement to animal testing for applications such as regulatory evaluations of pesticide toxicity. EPA and NIEHS scientists are evaluating CATMoS predictions for 178 chemicals in comparison to rat LD50 tests from publicly available ecological risk assessments registered from 1998 to 2020. Findings from this study will help in understanding the applicability of CATMoS estimates as a potential replacement of the rat acute single oral dose study for establishing the effects endpoint in ecological risk assessments.