# Technology

Many ICCVAM member agencies are developing new technologies and resources to replace the use of animals for chemical safety testing. These include new platforms such as microphysiological systems (MPS) and data resources to support the development of predictive models and adverse outcome pathways (AOPs).

## Assay Development

Many ICCVAM member agencies are developing new in vitro technologies and resources to replace animal use for chemical safety testing. Many of these include technologies to address important endpoints such as carcinogenicity, inhalation toxicity, and neurotoxicity.

### Two-dimensional cellular and three-dimensional bioprinted skin models to screen topical-use compounds for irritation potential

Tags: NIEHS, NIH, skin irritation

Assessing skin irritation potential is critical for the safety evaluation of topical drugs and other consumer products such as cosmetics. Use of animals for these evaluations is prohibited in some sectors, with advanced in vitro cellular models considered as possible replacements. To compare the utility of different cellular skin models for this purpose, scientists at the National Center for Advancing Translational Sciences (NCATS), the National Eye Institute, and the National Institute of Environmental Health Sciences (NIEHS) assessed irritation potential in different cellular skin models compatible with high-throughput screening (HTS) platforms (Wei et al. 2020). The study tested 46 compounds related to topical products on monolayer keratinocytes, reconstructed human epidermis, and full-thickness skin models, and evaluated performance of the models using generally accepted cellular and molecular indicators of irritant activity. The study indicated that using human cells to generate bioprinted tissue is a quick and reliable method to model human skin in a high-throughput manner, and that this approach could be used as evidence for hazard labeling in a variety of hazard classification systems.

### Human neuronal cell line as a model for organophosphorus pesticide-induced neurotoxicity

Tags: AOP, DoD, inhalation toxicity, neurotoxicity

Non-animal screening methods that can rapidly and accurately characterize organophosphorus compound-induced neurotoxicity are needed. Scientists at the U.S. Army Engineer Research and Development Center examined molecular and cellular responses characteristic of this neurotoxicity pathway via an in vitro model using the SYSY5Y human neuroblastoma cell line and the model organophosphorus compound ethyl parathion. In these studies, ethyl parathion was found to increase reactive oxygen species and cell membrane lipid peroxidation and reduce mitochondrial membrane potential, contributing ultimately to cell death. Overall, the mechanistic responses observed in the SYSY5Y cells corresponded closely with in vivo mammalian results, demonstrating potential for this non-animal model to provide accurate neurotoxicology screening for organophosphorus compounds. These investigations also provide data to support development of the AOP for this endpoint. In 2022, the research team will use these methods to investigate time-dynamic neurotoxicity responses to ethyl parathion. They will also begin developing in vitro methods that provide mechanistic toxicology indicators characteristic of mammalian acute ammonia inhalation exposures.

### Development of a non-animal-based vaccine test for RHDV2

Tags: NIEHS, USDA, antibodies, biologics

Rabbit hemorrhagic disease is a devastating disease affecting wild, farmed, and companion rabbits. The virus causing the disease is closely related to human norovirus. However, unlike norovirus, which rarely causes severe disease, rabbit hemorrhagic disease causes a syndrome culminating in the death of affected rabbits. The disease was historically not detected in the United States, but in 2020, rabbit hemorrhagic disease virus serotype 2 (RHDV2) was isolated from rabbits in Canada and has since caused significant outbreaks and mortality in the United States. While vaccines are available to prevent the disease, U.S. Department of Agriculture (USDA) licensing of an RHDV2 vaccine requires testing of each lot in live animals to confirm vaccine potency. To provide a non-animal alternative method for testing of a novel RNA-based vaccine, in 2021 NIEHS provided funding to optimize and qualify an in vitro potency assay that uses a monoclonal antibody specific for the RHDV2 target protein. Evaluation of the potency assay will be completed in 2022.

### Genetic toxicity screening approach for flavoring chemicals

Tags: FDA, carcinogenicity, genotoxicity, inhalation toxicity, QSAR, machine learning

A variety of compounds are used as flavorings for electronic nicotine delivery systems, or e-cigarettes. Scientists in the U.S. Food and Drug Administration (FDA) Center for Tobacco Products conducted a study (Hung et al. 2020 (https://pubmed.ncbi.nlm.nih.gov/32662109/)) using alternative methods as prioritization tools to study the genotoxic mode of action of these compounds. The approach specifically examined clastogen-sensitive and aneugen-sensitive biomarkers of DNA damage in human TK6 cells. These biomarkers were aggregated through a supervised three-pronged ensemble machine learning prediction model to prioritize chemicals based on genotoxicity. In addition, in silico quantitative structure–activity relationship (QSAR) models were used to predict genotoxicity and carcinogenic potential. The parallel use of these predictive technologies to clarify modes of action for potential genetic damage might be helpful for screening chemicals in tobacco products.

### Integration of transcriptome analysis with pathophysiological endpoints to evaluate cigarette smoke toxicity in an in vitro human airway tissue model

Tags: FDA, carcinogenicity, inhalation toxicity, mixtures toxicity, MPS, genotoxicity

To assess the effects of cigarette smoke on the function and phenotype of airway epithelial cells, scientists at the FDA Center for Tobacco Products and the FDA National Center for Toxicological Research developed a novel repeated-treatment protocol to evaluate the progression of molecular, functional, and structural abnormalities induced by cigarette smoke in a human in vitro air–liquid-interface airway tissue model (Xiong et al. 2021a (https://pubmed.ncbi.nlm.nih.gov/33660061/)). Transcriptomics analysis was combined with in vitro measurements to demonstrate cigarette smoke-mediated effects on a variety of cell functions. These measurements revealed effects that were highly consistent with abnormalities observed in airways of smokers. Enrichment analysis on the transcriptomic profiles of the air–liquid-interface cultures revealed key molecular pathways, such as xenobiotic metabolism, oxidative stress, and inflammatory responses, that were perturbed in response to cigarette smoke exposure. A subsequent study (Xiong et al. 2021b (https://pubmed.ncbi.nlm.nih.gov/33704509/)) described the transcriptome analyses of these cultures and noted that cultures exposed to the high concentration of cigarette smoke exhibited 5,090 differentially expressed genes and 551 differentially expressed microRNAs. Expression of genes involved in ciliary development and function were significantly perturbed by repeated cigarette smoke exposures, leading to changes in protein content and cilia beating frequency. In particular, the expression of miR-449a, a conserved miRNA highly enriched in ciliated airway epithelia and implicated in motile ciliogenesis, showed a time-dependent decrease following cigarette smoke, an effect consistent with observations reported in smokers with chronic obstructive pulmonary disease. Investigating the effects of cigarette smoke on the transcriptome profile of human air–liquid-interface cultures may provide both mechanistic insights and potential early biomarkers for harm from cigarette smoke exposure.

### In vitro dosimetry analyses for acrolein exposure in human cells

Tags: FDA, AOP, genotoxicity

Establishing accurate dosimetry is important for assessing the toxicity of xenobiotics as well as for comparing responses between different test systems. Scientists at the FDA Center for Tobacco Products and the FDA National Center for Toxicological Research used acrolein as a model toxicant and defined the concentration–response relationships of the key adverse responses in both normal human bronchial epithelial cells and human pulmonary carcinoma cells (Xiong et al. 2021 (https://pubmed.ncbi.nlm.nih.gov/33385576/)). The researchers developed a new method for indirectly estimating the intracellular uptake of acrolein based on the chemical’s key alkylation reactions. Responses, including protein carbonylation, glutathione depletion, and glutathione–acrolein adduct formation, were all linearly correlated with acrolein uptake in both cell types. The study demonstrated that normal human bronchial epithelial cells were more sensitive to acrolein exposure than the pulmonary carcinoma cells and provided mechanistic information about acrolein-induced cytotoxicity. The dosimetric analysis presented in this study may provide useful information for computational modeling and risk assessment of acrolein using different test systems.

### Development of cellular and molecular approaches to evaluate effects of environmental contaminants and stressors in fish

Tags: DOI, ecotoxicity, endocrine disruptors, hepatotoxicity

Aquatic exposure to endocrine disruptors, pesticides, and cyanobacteria affects the health of fish in the environment. Most of the affected species are not typically used in the laboratory and their specific responses to such exposure cannot always be inferred from data from laboratory species. During 2020-2021, scientists in the U.S. Geological Survey (USGS) of the U.S. Department of the Interior (DOI) developed and applied methods to evaluate species-specific cellular and molecular responses to environmental contaminants and thermal stress using primary tissue culture and non-lethal biopsy methods. Specifically, this research focused on brook trout, largemouth bass, and smallmouth bass collected from the upper Chesapeake Bay watershed. Methods used included evaluation of gill biopsy tissue and collection of primary hepatocytes and leukocytes from species that inhabit aquatic ecosystems vulnerable to environmental contamination and thermal stress. Analytical approaches included in vitro exposures, image analysis-based flow cytometry, and transcriptional profiling of gill, hepatic and immune-responsive genes using RNA-seq and nCounter technologies. These approaches are used to investigate specific mechanistic questions in environmentally relevant fishes to minimize the use of vertebrates.

## Computational Tools Development

Computationally generated predictions of toxicity endpoints can inform decisions about testing priorities and sometimes eliminate the need for laboratory testing. ICCVAM agencies are developing tools to predict toxicity endpoints such as acute oral toxicity, skin sensitization, and genotoxicity, as well as tools to provide in vivo context to in vitro data through in vitro to in vivo extrapolation (IVIVE).

### Collaborative Acute Toxicity Modeling Suite (CATMoS) tool for predicting acute oral toxicity

Tags: ICCVAM, EPA, NIEHS, acute toxicity, oral toxicity, ecotoxicity

There is a pressing need to rapidly and accurately assess the safety of environmental chemicals and reduce the number of animals used in regulatory testing while still protecting wildlife. NICEATM and the ICCVAM Acute Toxicity Workgroup organized a global collaborative project to develop predictive in silico models of acute oral systemic toxicity potential. Participants from 35 international groups submitted a total of 139 models built using a data set of 11,992 chemicals split into training (75%) and evaluation (25%) sets. These crowdsourced models were developed for five endpoints identified as relevant to regulatory decision frameworks: (1) LD50 value, (2) U.S. Environmental Protection Agency (EPA) hazard categories, (3) United Nations Globally Harmonized System of Classification and Labelling of Chemicals (GHS) hazard categories, (4) very toxic chemicals (LD50 <50 mg/kg), and (5) non-toxic chemicals (LD50 >2,000 mg/kg). Predictions within the applicability domains of the submitted models were evaluated and combined into consensus predictions based on a weight-of-evidence approach. The result, the Collaborative Acute Toxicity Modeling Suite (CATMoS; Mansouri et al. 2021), leverages the strengths and overcomes the limitations of individual modeling approaches. The consensus model predictions are fully reproducible and demonstrate equivalent performance to replicate in vivo data considering the inherent variability, offering a strong potential replacement for animal testing. Based on these results, CATMoS predictions for 178 chemicals are currently being evaluated in comparison to rat acute oral toxicity tests from publicly available ecological risk assessments registered from 1998 to 2020. Findings will inform the potential for using CATMoS estimates to potentially replace data from rat acute oral toxicity studies for assessments of ecological risk (i.e., what assumptions might be made, under what conditions, and which chemicals).

### CompTox Chemicals Dashboard

Tags: EPA

The CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard) is the primary web-based application that provides access to data and algorithms from the EPA Center for Computational Toxicology and Exposure. Since April 2017, a total of 10 releases have increased the data available from an initial release of 560k data points to a total of 906k data points with the December 2021 release. There are now over 310 individual chemical lists available that include substances such as pesticides, disinfectant byproducts, and PFAS. The latest release represents a major architecture and design update, with data management based on a datamart-datahub technology, a rich application programming interface (API), and fresh user interface design. With this architecture, new applications using the same underpinning data and API will be easier to build and maintain long-term. The update also supported significant improvements in performance. For example, batch searches and downloads for 5000 chemicals now generally take less than 5 seconds compared with over a minute in the previous version. Both Generalized Read-Across (GenRA) and Abstract Sifter are now separate modules, allowing their use for querying chemicals beyond those present in the underlying database. The next release of data, planned for 2022, will expand the number of substances to over 1.2 million chemicals and will include updates to many of the existing chemical lists.

### Open (Quantitative) Structure–activity/property Relationship App (OPERA)

Tags: EPA, NIEHS, IVIVE, QSAR

The Open (Quantitative) Structure–activity/property Relationship App (https://ntp.niehs.nih.gov/go/opera) (OPERA) is a free and open-source/open-data suite of QSAR models developed to support a range of research and regulatory purposes. In addition to physicochemical and environmental fate properties, OPERA offers a number of models predicting absorption, distribution, metabolism, and excretion (ADME) endpoints that are important to physiologically based pharmacokinetic (PBPK) modeling and IVIVE studies. The OPERA ADME-related endpoints were added during 2020 and 2021 and include models for octanol/water partition and distribution coefficients, acidic dissociation, fraction of chemical unbound to plasma protein, intrinsic hepatic clearance, and Caco2 permeability. All OPERA models were built using curated data sets split into training and test sets and molecular descriptors developed from standardized QSAR-ready chemical structures. Modeling adhered to the five principles for QSAR model development adopted by the Organisation for Economic Co-operation and Development (OECD). These principles support development of scientifically valid, high accuracy models with minimal complexity that support mechanistic interpretation, when possible.

Existing OPERA models are updated regularly when new experimental data are available. Recently, the models for octanol/water partition coefficient, fraction unbound, and intrinsic clearance were updated with the latest publicly available data sets to improve their predictivity and applicability domain coverage. For consistency and transparency, OPERA also provides a tool for standardizing chemical structures, an estimate of prediction accuracy, an assessment of applicability domain, and incorporation of experimental values when available. Technical and performance details are described in OECD-compliant QSAR Model Reporting Format reports. OPERA predictions are available through the EPA CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard) and the National Toxicology Program’s (NTP’s) Integrated Chemical Environment (https://ice.ntp.niehs.nih.gov/). The OPERA application can also be downloaded from the NIEHS GitHub repository (https://github.com/NIEHS/OPERA) as a command-line or graphical user interface for Windows and Linux operating systems.

### Integrated Chemical Environment (ICE) tools updates

Tags: NIEHS, Tox21, EPA, IVIVE

The NTP’s Integrated Chemical Environment (https://ice.ntp.niehs.nih.gov/) (ICE) provides data and tools to help develop, assess, and interpret chemical safety tests. Updates to ICE during 2020 and 2021 launched several new tools and implemented substantive updates to existing tools.

- The Search tool now allows search results to be sent directly to other ICE tools, the EPA CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard), and the NTP Chemical Effects in Biological Systems (https://cebs.niehs.nih.gov/cebs/) database. Visualization features implemented in March 2021 help users explore query results in more detail.
- Improvements to the IVIVE tool allowed users the option to upload their own in vitro data for IVIVE analysis and their own in vivo data for visualizing comparisons to IVIVE predictions, as opposed to being limited to using data available in ICE. An inhalation model was added to the IVIVE tool in October 2020. The tool now also allows assay selection based on mode of action and user specification of whether experimental or predicted data are used for ADME parameters. Results can also be filtered by mode of action or toxicity endpoint annotation.
- New visualization features in the Chemical Characterization tool help users better understand the relationships between members of a chemical set and lets users explore chemical use categories from the EPA’s Consumer Products database.
- Curve Surfer, launched in March 2021, allows users to view and interact with concentration–response curves from curated HTS data.
- The PBPK tool, launched in March 2021, uses models from the EPA’s httk package (https://cran.r-project.org/web/packages/httk/index.html) to generate predictions of tissue-specific chemical concentration profiles following a dosing event.
- Chemical Quest, launched in June 2021, uses Saagar molecular fingerprints (Sedykh et al. 2021) to identify chemicals in the ICE database having similar structures to a query chemical, which can be entered using chemical identifiers or structure drawings.

Improvements to all tools during 2020 and 2021 include organization of data from the EPA Toxicity Forecaster (ToxCast) and the U.S. government’s interagency Tox21 programs into query setup menus based on mechanistic targets and modes of action. Other improvements included mapping of ToxCast and Tox21 assays to controlled terms from the National Cancer Institute (NCI) Metathesaurus (https://ncimetathesaurus.nci.nih.gov/ncimbrowser/); new tooltips and information buttons to help users set up queries; and the acceptance of a variety of chemical identifier types as query inputs.

### Pred-Skin web portal for predicting human skin sensitizers

Tags: NIEHS, skin sensitization, QSAR

In collaboration with scientists at the University of North Carolina at Chapel Hill and the Universidade Federal de Goiás, NICEATM scientists contributed to the development of a model to predict skin sensitization potential of chemicals for two assays, the human patch test and murine local lymph node assay, and implemented this model in a web portal (Braga et al. 2017 (https://pubmed.ncbi.nlm.nih.gov/28459556/)). Pred-Skin v. 3.0 (http://predskin.labmol.com.br/) (Borba et al. 2021) revised and expanded the freely accessible web tool to integrate multiple QSAR models developed with in vitro, animal in vivo, and human predictive patch test data into a consensus naïve Bayes model that predicts human effects.

### Large-scale modeling of multispecies acute toxicity endpoints using consensus of multitask deep learning methods

Tags: NCI, NIEHS, NIH, acute toxicity, machine learning

Scientists from NCATS, NIEHS, and NCI and collaborators developed computational methods to predict chemical activity for 59 acute systemic toxicity endpoints across multiple species, including 36 endpoints for which computational models had not been previously developed. Data used to develop the models were collected and curated from the ChemIDplus (https://chem.nlm.nih.gov/chemidplus/) database for acute systemic toxicity and represents the largest publicly available such data set, covering over 80,000 compounds. These data were used for developing multiple single- and multitask models utilizing random forest, deep neural networks, convolutional, and graph convolutional neural network approaches. The paper describing the project (Jain et al. 2021) also reports the consensus models based on different multitask approaches. The curated data set and the developed models have been made publicly available (https://github.com/ncats/ld50-multitask) to support regulatory and research applications.

### Saagar–a new, extensible set of molecular substructures for QSAR/QSPR and read-across predictions

Tags: NIEHS, QSAR

To improve utility and interpretability of molecular structure-based predictive models, NIEHS scientists and collaborators developed a novel set of extensible chemistry-aware substructures, Saagar. The Saagar features were systematically identified based upon open-source literature highlighting relationships among substructural moieties, physicochemical properties, toxicological properties of molecules, and ADME properties. This development approach makes Saagar features more interpretable than standard molecular descriptor libraries. The Saagar substructures were evaluated for their performance in chemical characterization and read-across applications by comparing results with four publicly available fingerprint sets for three benchmark chemical sets including about 145,000 compounds (Sedykh et al. 2021). In 18 of the 20 comparisons, Saagar features performed better than the other fingerprint sets. Saagar features efficiently characterize diverse chemical collections, thus making them a better choice for building interpretable predictive in silico QSAR models and read-across protocols.

### Tox21BodyMap: a webtool to map chemical effects on the human body

Tags: EPA, NIEHS, Tox21

To support rapid chemical toxicity assessment and mechanistic hypothesis generation, EPA and NIEHS scientists developed an intuitive webtool allowing a user to identify target organs in the human body where a substance is predicted to be more likely to produce effects (Borrel et al. 2020). This tool, Tox21BodyMap (https://sandbox.ntp.niehs.nih.gov/bodymap/), incorporates results of 9,270 chemicals tested in the United States federal Tox21 research consortium using 971 HTS assays whose targets were mapped onto human organs using organ-specific gene expression data. Via Tox21BodyMap’s interactive tools, users can visualize chemical target specificity by organ system and implement different filtering criteria by changing gene expression thresholds and activity concentration parameters. Dynamic network representations, data tables, and plots with comprehensive activity summaries across all Tox21 HTS assay targets provide an overall picture of chemical bioactivity.

### Tools to predict chemical-assay interference

Tags: EPA, NIEHS, NIH, Tox21, machine learning

Assays used in Tox21 and other HTS programs rely on luciferase and fluorescence-based readouts. These can be susceptible to signal interference by certain chemical structures resulting in false positive outcomes. However, the Tox21 portfolio includes assays specifically designed to measure interference in the form of luciferase inhibition and autofluorescence via multiple wavelengths and under various conditions. EPA, NIEHS, and NCATS scientists applied multiple machine learning algorithms to predict assay interference based on molecular descriptors and chemical properties (Borrel et al. 2020a (https://www.nature.com/articles/s41598-020-60747-3)). The best performing predictive models were incorporated into a web-based tool called InterPred (https://sandbox.ntp.niehs.nih.gov/interferences/) (Borrel et al. 2020b (https://academic.oup.com/nar/article/48/W1/W586/5838861)) that allows users to predict the likelihood of assay interference for any new chemical structure. InterPred increases confidence in HTS data by decreasing false positive testing results.

### SARA model for prediction of skin sensitization

Tags: NIEHS, skin sensitization

In May 2021, NICEATM entered into an agreement with consumer products company Unilever to collaboratively test and further develop their Skin Allergy Risk Assessment (SARA) predictive model (Reynolds et al. 2019 (https://www.sciencedirect.com/science/article/pii/S2468111318300872)). SARA is a computational model that uses a variety of input data to estimate a probability that a chemical will cause an allergic skin reaction in humans. NICEATM will test the SARA model using a variety of chemical data sets, including chemicals of interest to U.S. and international regulatory agencies. NICEATM and Unilever will also work together to expand the SARA model to include data generated by the NIEHS Division of the NTP (DNTP). The intent is to make the SARA model openly available for public use along with other NICEATM predictive models. Availability of the SARA model will help further reduce animal use for the endpoint of skin sensitization and will improve upon existing efforts by providing points of departure (PODs) for quantitative human risk assessment.

### Computational models for eye irritation classification of mixtures

Tags: NIEHS, eye irritation, mixtures toxicity

NIEHS scientists developed of a set of computational models to predict eye irritation and corrosion (Sedykh et al. 2022 (https://doi.org/10.1021/acs.chemrestox.1c00443)). The models were developed using a curated database of in vivo eye irritation studies from the scientific literature and stakeholder-provided data. The database contained over 500 unique substances, including many mixtures, tested at different concentrations. Substances were categorized according to GHS and EPA hazard classifications. Two modeling approaches were used to predict classification of mixtures. A conventional approach generated predictions based on the chemical structure of the most prominent component of the mixture. A mixture-based approach generated predictions by using weighted feature averaging to consider all known components in the mixture. Results suggest that these models are useful for screening compounds for eye irritation potential. Future efforts to increase the models’ utility will focus on expanding their applicability domains and using them in conjunction with other input variables (e.g., in vitro data) to establish defined approaches for eye irritation testing.

### Incorporating parameter and population variability into PBPK modeling

Tags: NIEHS, IVIVE, QSAR

To identify the potential for a chemical to be of concern to sensitive populations, it is important for new approach methodologies (NAMs) to characterize variations in metabolism that can affect toxicity within a population of interest. NIEHS scientists are incorporating the effects of genetic variability on ADME into pharmacokinetic models. These models can be used to predict a tissue concentration from an external exposure (forward dosimetry) or estimate an external exposure that would result in a plasma or tissue concentration equivalent to an effective concentration in an in vitro assay (reverse dosimetry). The models use inputs from ADMET Predictor software (https://www.simulations-plus.com/software/admetpredictor) (Simulations Plus, Inc.) to characterize what enzymes might be involved in a chemical’s metabolism and the structure and proportions of metabolites produced. Work is ongoing to identify polymorphisms in the genes coding for enzymes that might affect metabolism, characterize the polymorphisms’ prevalence within populations, and incorporate this information into IVIVE and PBPK models. The OPERA QSAR modeling suite will then be used to predict a range of resulting toxicities for chemical metabolites.

### Web application to apply skin sensitization defined approaches to user data

Tags: NIEHS, skin sensitization

In June 2021, OECD issued Guideline 497, Defined Approaches on Skin Sensitisation (https://www.oecd-ilibrary.org/environment/guideline-no-497-defined-approaches-on-skin-sensitisation_b92879a4-en), the first internationally harmonized guideline to describe a non-animal approach to predict skin sensitization potential. NICEATM scientists are developing an interactive web application that computationally applies the defined approaches outlined in Guideline 497 through a user-friendly interface. The user uploads data from the test methods used in the defined approach to the web application, which then generates skin sensitization predictions for the user’s chemicals of interest. The user selects the analysis variables, and the application dynamically provides feedback about the user’s data set to identify problematic data values. The application is still in development and will be available on the NTP website in 2022.

### Development of a human intestinal cell permeability model

Tags: NIEHS

Intestinal absorption plays a role in the toxicity of chemicals. The human Caco-2 cell line, derived from human colon epithelial cancer cells, is currently used in an in vitro model of human intestinal absorption. However, there are several limitations to this method, including long cell culture times and inability to conduct HTS. NIEHS scientists are developing computational models for chemical absorption in human intestines that would allow for screening a wide range of chemicals for potential intestinal permeability, which would assist in evaluating the toxicity potential of these chemicals. To date, a data set containing over 4,500 unique chemicals has been compiled and prepared; development of a model is planned for 2022.

### Investigating DNA adduct formation by flavor chemicals and tobacco byproducts in e-cigarettes using in silico approaches

Tags: FDA, carcinogenicity, inhalation toxicity, mixtures toxicity, genotoxicity, skin sensitization, QSAR

The potential harms from inhaling flavoring chemicals used in e-cigarettes and byproducts of those chemicals have not been extensively studied. One mechanism of interest is DNA adduct formation, which may lead to carcinogenesis. Scientists at the FDA Center for Tobacco Products (Kang and Valerio 2020) determined that flavoring chemicals and their byproducts include alkenylbenzenes and aldehydes, both of which are known to form DNA adducts. Using in silico toxicology approaches, they conducted a structural similarity analysis and generated in silico model predictions of these chemicals for genotoxicity, mutagenicity, carcinogenicity, and skin sensitization. Good concordance was observed between DNA adduct formation and models predicting mammalian mutagenicity and skin sensitization for both chemical classes. On the other hand, different prediction profiles were observed for the two chemical classes for the endpoints of unscheduled DNA synthesis and bacterial mutagenicity. These results are likely due to the different mode of action between the two chemical classes, as aldehydes are direct acting agents, while alkenylbenzenes require bioactivation to form the electrophilic intermediates that in turn form DNA adducts. This study suggests that in silico prediction for the mouse lymphoma assay may serve as a surrogate endpoint to help predict DNA adduct formation for chemicals found in tobacco products such as flavors and byproducts.

### Using in silico toxicology tools to predict mutagenic potential of tobacco products

Tags: FDA, carcinogenicity, inhalation toxicity, mixtures toxicity, QSAR, genotoxicity, metrics

Scientists at the FDA Center for Tobacco Products (Goel and Valerio 2020 (https://pubmed.ncbi.nlm.nih.gov/32752976/)) utilized in silico tools to predict the mutagenic potential of chemicals in tobacco products and tobacco smoke in a validation test and in a separate screening test. Publicly available QSAR models were validated against 900 chemicals relevant to tobacco products for which experimental Ames mutagenicity data were available from public sources. The predictive performance of the individual and combined QSAR models was evaluated using various performance metrics. All the models performed well, predicting mutagens and nonmutagens with 75%-95% accuracy, 66%-94% sensitivity, and 73%-97% specificity. Subsequently, in a screening test, a combination of complementary structure–activity relationship and QSAR models was used to predict the mutagenicity of 6,820 chemicals cataloged in tobacco products and/or tobacco smoke. More than 1,200 of these chemicals were predicted to have mutagenic potential, with 900 potential mutagens in tobacco smoke. This research demonstrates the validity of in silico QSAR tools to predict mutagenicity of chemicals in tobacco products or tobacco smoke, and suggests QSAR models may be useful as screening tools for hazard identification to inform tobacco regulatory science.

### Using in silico approaches to explore the potential neurotoxicity of vaping vitamin E or vitamin E acetate

Tags: FDA, carcinogenicity, inhalation toxicity, mixtures toxicity, QSAR, neurotoxicity

Serious adverse health effects have been reported with the use of vaping products, including neurologic disorders and e-cigarette or vaping product use-associated lung injury. Vitamin E acetate, often added as a diluent to cannabis-containing products, has been linked to lung injury. FDA scientists explored the relationship of such additives to neurotoxicity. Literature searches were performed on vitamin E and vitamin E acetate-associated neurotoxicity. The literature review showed that the neurotoxic potential of inhalation exposures to these compounds in humans is unknown. The blood-brain barrier penetration potential of vitamin E and vitamin E acetate were evaluated using cheminformatic techniques. Physicochemical properties suggest that these compounds are lipophilic, and molecular weights indicate vitamin E and vitamin E acetate have the potential for blood-brain barrier permeability. Computational models also predict both compounds may cross the blood-brain barrier via passive diffusion. The literature search found no experimental nonclinical studies or clinical information on the neurotoxic potential of vitamin E via inhalation. However, neurotoxic effects of phenyl acetate, a pyrolysis by-product structurally analogous to vitamin E acetate, suggest that vitamin E acetate has potential for central nervous system impairment. Cheminformatic model predictions provide a theoretical basis for potential central nervous system permeability of these inhaled dietary ingredients, suggesting that they should be prioritized to evaluate for potential central nervous system hazard.

### Development of a nicotinic acetylcholine receptor binding activity prediction model

Tags: FDA, carcinogenicity, inhalation toxicity, mixtures toxicity

Addiction to nicotine found in tobacco products causes difficulty in quitting among users. Nicotinic acetylcholine receptors (nAChRs) are the physiological targets of nicotine and facilitate addiction to tobacco products, primarily the nAChR-α7 subtype. Therefore, predicting the binding activity of tobacco constituents to nAChR-α7 is an important component for assessing addictive potential of tobacco constituents. Scientists at the FDA Center for Tobacco Products developed a predictive computational model for nAChR-α7 binding activity. The model was trained on data from 843 chemicals with human nAChR-α7 binding activity extracted from PubChem and the European Union’s ChEMBL chemicals database (Sakkiah et al. 2020 (https://pubmed.ncbi.nlm.nih.gov/32159345/)). The model was tested using 1,215 chemicals with rat nAChR-α7 binding activity data from the same databases. The developed model was then used to predict the potential human nAChR-α7 binding activity for 5,275 tobacco constituents. The human binding activity data for 84 of the 5,275 tobacco constituents were experimentally measured to validate the prediction results. This model of human nAChR-α7 binding may be a useful tool for screening of potentially addictive tobacco constituents.

### Deep learning image analysis of high-throughput toxicology assay images

Tags: NIEHS, machine learning

HTS (high-throughput screening) approaches often employ microscopy to capture photomicrographs from multi-well cell culture plates, generating thousands of images that require manual human analysis. To automate this subjective and time-consuming process, NIEHS scientists and collaborators developed a method that uses deep learning to automatically classify digital assay images (Tandon et al. 2021). A convolutional neural network was trained to perform binary and multiclass classification. The binary classifier accurately binned assay images into healthy (comparable to untreated controls) and altered (not comparable to untreated controls) classes, while the multiclass classifier accurately assigned “Healthy,” “Intermediate,” and “Altered” labels to assay images. The study results indicated a strong correspondence between dosage and classifier-predicted scores, suggesting that these scores might be useful in further characterizing benchmark dose. Together, these results clearly demonstrate that deep learning-based automated image classification of cell morphology changes upon chemical-induced stress can yield highly accurate and reproducible assessments of cytotoxicity across a variety of cell types.

### Derek Nexus QSAR software for predicting skin sensitization and EC3 values

Tags: DoD, skin sensitization, QSAR

Traditionally, skin sensitization potential of chemicals has been determined using in vivo methods. One of these methods, the mouse lymph node assay, expresses the potential of a chemical to cause skin sensitization as an EC3 value: the concentration of a chemical required to elicit a threshold positive response. Scientists at the U.S. Air Force Research Laboratory explored approaches that use in silico and in vitro assays (Naumann and Arnold 2019 (https://doi.org/10.1177/0748233719875365)) to calculate EC3 values and develop safe surface levels for chemicals used in fabrication and maintenance shops. A list of 125 relevant chemicals was compiled for evaluation of their skin sensitization potential using this approach. Of those chemicals, 21 known sensitizers have been identified, and an additional 58 chemicals were identified as having insufficient information available to determine sensitization potential. To support the analysis, additional in vitro testing was completed on a number of chemicals using two assays for skin sensitization potential, the direct peptide reactivity assay and the KeratinoSens assay. QSAR analysis using a nearest-neighbors approach was performed on the known sensitizers and measured or predicted EC3 values were obtained using Derek Nexus software (https://www.lhasalimited.org/products/derek-nexus.htm) (Lhasa Limited). Of the 58 chemicals lacking sensitization or toxicity data, predictions of sensitizing potential were also obtained using both Derek Nexus and publicly available OECD QSAR Toolbox software (https://www.oecd.org/chemicalsafety/risk-assessment/oecd-qsar-toolbox.htm) and results compared with six chemicals identified as potential sensitizers. Very few differences in sensitizer vs. nonsensitizer predictions of sensitization potential were found. The EC3 values derived from these efforts will be used to calculate surface levels. In vitro test results generated for the project will also be made available to update current in silico models of skin sensitization.

### Continued development of httk

Tags: DoD, EPA, NIEHS, developmental toxicity, inhalation toxicity, IVIVE

To fully characterize the potential human health risk of a substance, data are often needed on that substance’s toxicokinetics: how a substance is absorbed, distributed, metabolized, and eliminated in the body. Traditional approaches for obtaining toxicokinetics data use animals, but alternative approaches are being developed to computationally estimate toxicokinetic parameters. Scientists within EPA and the U.S. Air Force Research Laboratory are developing such an approach to generate high-throughput toxicokinetic estimates of chemical inhalation exposures (Linakis et al. 2020 (https://doi.org/10.1038/s41370-020-0238-y)). This approach has been implemented in an inhalation component for the R-based high-throughput toxicokinetics (https://cran.r-project.org/web/packages/httk/index.html) (httk) package. In total, 142 exposure scenarios across 41 volatile organic chemicals were modeled and compared to published data. Ongoing work is focused on development of inhalation models for aerosols and mixed exposures. To better model and evaluate fetal exposure to environmental chemicals, EPA scientists have also developed a gestational model component for httk, which estimates the chemical concentrations in multiple fetal tissues (Kapraun et al. 2019 (https://doi.org/10.1371/journal.pone.0215906), Kapraun et al. 2022 (https://doi.org/10.1093/toxsci/kfac084)). The gestational model has been used for IVIVE analysis by NICEATM to evaluate fetal exposures that cause developmental toxicity risk. NICEATM scientists have also actively participated in testing of httk and review of its code, data, and documentation.

### Evaluation of QSAR models for predicting metabolic parameters

Tags: DoD, mixtures toxicity, QSAR

To fully characterize the potential human health risk of a substance, data are often needed about a substance’s toxicokinetics to understand how it is absorbed, distributed, metabolized, and eliminated in the body. Traditional approaches for obtaining toxicokinetics data use animals, but alternative approaches are being developed to computationally estimate toxicokinetic parameters in silico using QSAR models. Scientists at the U.S. Air Force Research Laboratory (Sweeney and Sterner 2022 (https://doi.org/10.1016/j.comtox.2022.100214)) evaluated QSAR models that use chemical structure or property information to predict two toxicokinetic parameters: the maximal capacity for metabolism (Vmax) and the half-maximal concentration for metabolism (KM). None of the evaluated QSAR models in their published forms could be fully validated. Literature review, use of graphical information, and other strategies allowed the deficiencies to be addressed for QSAR predictions of these parameters for alkylbenzenes, volatile organic chemicals, and substrates of alcohol dehydrogenase, aldehyde dehydrogenase, cytochrome P450, and flavin-containing monooxygenases. The updated QSAR expressions for smaller data sets tended to show greater accuracy in Vmax and KM prediction than larger data sets, and Vmax was generally more accurately predicted than KM. In a feasibility case study, the QSAR models were used to estimate toxicokinetic parameters of jet fuel components to determine the potential utility of this approach for investigation of mixture toxicokinetics. Results suggested that the models performed better to predict toxicokinetic parameters of volatile organic chemicals and alkylbenzenes as compared to cytochrome P450 substrates, likely due to the physicochemical properties of the chemicals used in the models’ development.

### Molecular docking and deep learning to predict binding and activity of compounds on neurological targets

Tags: DoD, neurotoxicity, machine learning

Airmen are exposed to hundreds of chemicals in the operational environment. Some of these chemicals can interact with proteins in the brain and cause neurotoxic effects impairing memory and cognitive performance. To address the need for rapid assessment of neurotoxicity of chemicals, scientists at the U.S. Air Force Research Laboratory developed an in silico tool that uses a reverse molecular docking approach to identify receptor targets for chemicals (McCarthy et al. 2022 (https://doi.org/10.1016/j.comtox.2022.100238)). They also developed deep learning computational models that predict activity at the neurological targets. The chemical assessment process was automated via a Python-based graphical user interface that prepares all necessary files and performs docking and deep learning modeling. This is a novel tool that can potentially be used to screen and assess chemicals of interest for possible neurotoxic effects that can impact cognitive performance of airmen.

### Structure-based QSAR models to predict repeat-dose toxicity points of departure

Tags: EPA, QSAR

Data gap filling techniques, such as QSAR models based on chemical structure information, can predict potential hazards of chemicals that have little experimental data. Risk assessment requires identification of a quantitative POD value, the lowest dose or concentration at which a treatment-related response is observed; effects of treatment by lower doses must be estimated by low-dose extrapolation. A study by EPA scientists (Pradeep et al. 2020 (https://pubmed.ncbi.nlm.nih.gov/34017928/)) describes two sets of QSAR models to predict POD values for repeat-dose toxicity. The first set of QSAR models predicts point estimates of POD values using structural and physicochemical descriptors for repeat-dose study types and species combinations. The second set of QSAR models predicts the 95% confidence intervals for PODs using a constructed POD distribution based on previously published typical study-to-study variability that may lead to uncertainty in model predictions (Pham et al. 2020 (https://pubmed.ncbi.nlm.nih.gov/33426408/)). Enrichment analysis to evaluate the accuracy of the predicted PODs showed that 80% of the 5% most potent chemicals were found in the top 20% of the most potent chemical predictions. This suggests that these repeat-dose POD QSAR models may help inform screening-level human health risk assessments in the absence of other data.

## Data Resources

As momentum grows toward adoption of alternatives to animal use for chemical safety testing, curated data are needed to support method validation and establish scientific confidence in new approaches. ICCVAM agencies address that need by compiling data and making them publicly available.

### Semi-automated extraction of literature data using machine learning methods

Tags: DOE, FDA, NIEHS, developmental toxicity, machine learning, endocrine disruptors

NICEATM, other scientists within DNTP, the Oak Ridge National Laboratory (U.S. Department of Energy [DOE]), and FDA are collaborating to automate the process of identifying high-quality developmental toxicity studies in the published scientific literature. The approach applies natural language processing and machine learning methods to identify specific data elements in the full text of scientific publications using both unsupervised and supervised approaches.

Preliminary models were trained using a uterotrophic database (Kleinstreuer et al. 2016 (https://www.ncbi.nlm.nih.gov/pubmed/26431337)) built for the EPA Endocrine Disruptor Screening Program. The models leveraged natural language processing and multivariate machine learning models to identify papers that meet minimum criteria to be considered guideline-like studies (Herrmannova et al. 2018 (https://arxiv.org/abs/1811.01183)). Supervised and unsupervised approaches were developed to automatically extract text features that correspond to study descriptors and classify papers based on their adherence to minimum criteria derived from regulatory guideline studies. These methods demonstrated high cross-validated performance on the uterotrophic training set.

This work is being extended and applied to automate the identification of high-quality prenatal developmental toxicity studies in the literature, in collaboration with the ICCVAM Developmental and Reproductive Toxicity Expert Group. A publication describing this work is being drafted for submission in 2022.

### Extraction and annotation of legacy developmental toxicity study data

Tags: NIEHS, developmental toxicity

To support the evaluation of non-animal approaches for developmental toxicity assessment, NICEATM scientists extracted information from more than 100 legacy NTP prenatal developmental toxicity animal studies and a subset of about 50 studies submitted to the European Chemicals Agency that were deemed high-quality by NTP subject matter experts. Study details extracted included species, strain, administration route, dosing duration, and treatment-related effects.

The extracted data were standardized by applying controlled vocabularies and ontologies to facilitate computational analyses and integration with other structured databases such as EPA’s Toxicity Reference Database (ToxRefDB). Elements of three controlled vocabularies (the Unified Medical Language coding system, the German Institute for Risk Assessment DevToxDB ontology, and the OECD Harmonised Template 74 terminologies) were combined with automation code to programmatically standardize primary source language of extracted developmental toxicology endpoints. This work aims to reduce manual labor, facilitate further analyses (e.g., systematic review, model-building, NAM validation), and uphold findability, accessibility, interoperability, and reusability (FAIR) principles. A poster describing this work (Foster et al. (https://ntp.niehs.nih.gov/iccvam/meetings/11wc/foster-wc11_508.pdf)) was presented at the 11th World Congress (https://ntp.niehs.nih.gov/whatwestudy/niceatm/publications-and-presentations/presentations-at-scientific-meetings/wc11/index.html) on Alternatives and Animal Use in the Life Sciences, and a publication is being drafted for submission in 2022.

### Compilation of human skin sensitization data

Tags: CPSC, FDA, NIEHS, skin sensitization

Appropriate evaluation of NAMs requires reference data for assessing a NAM’s ability to predict an outcome of interest. Human data provide the most relevant basis for such comparisons, but they are rarely available due to obvious ethical issues associated with toxicology testing in humans. One exception is data from skin sensitization tests that are routinely conducted using a wide range of materials. For this project, U.S. Consumer Product Safety Commission (CPSC), FDA, and NICEATM scientists and collaborators collected data from 2,277 human predictive patch tests conducted under two protocols: the human repeat insult patch test and the human maximization test. Data were collected from more than 1,500 publications. The data collection process also captured protocol elements and positive or negative outcomes, calculated traditional and non-traditional dose metrics, and developed a scoring system to evaluate each test for reliability. The resulting database, which contains information for 1,366 unique substances, was characterized for physicochemical properties, chemical structure categories, and protein binding mechanisms. A description of the database (Strickland et al. (https://ntp.niehs.nih.gov/iccvam/meetings/ascct-2021/strickland_hppt_ascct2021_508.pdf)) was presented at the 2021 annual meeting (https://ntp.niehs.nih.gov/whatwestudy/niceatm/publications-and-presentations/presentations-at-scientific-meetings/ascct-2021/ascct-2021.html) of the American Society for Cellular and Computational Toxicology, and a publication is being drafted for submission in 2022. The data are publicly available via ICE to serve as a resource for the development and evaluation of NAMs for skin sensitization testing.

### Integrated Chemical Environment data updates

Tags: NIEHS, Tox21, metrics, carcinogenicity, developmental toxicity, genotoxicity, skin irritation, skin sensitization

NICEATM’s Integrated Chemical Environment (https://ice.ntp.niehs.nih.gov/) (ICE) provides data and tools to help develop, assess, and interpret chemical safety tests. Updates to ICE data sets during 2020 and 2021 provided additional metadata in downloads of query results, updated curated HTS data, and new data in these areas:

- Skin irritation: in vivo and in vitro data.
- Cancer/genotoxicity: reference chemical lists and in vitro and in vivo data.
- Developmental and reproductive toxicity: in vivo data.
- Skin sensitization: data from human predictive patch tests.
- Chemical property predictions from OPERA.

### Variability analysis of in vivo skin irritation data to use in establishing confidence for alternative methods

Tags: NIEHS, skin irritation

A limiting factor in identifying a complete in vitro replacement for the standard in vivo skin irritation test could be the variability inherent to the subjective scoring of endpoints in the in vivo test. This is particularly relevant for mild and moderate irritants, where interindividual differences in scoring are most likely to occur. To characterize the reproducibility of the in vivo assay, NICEATM assessed variability in study results from substances tested multiple times (Rooney et al. 2021). A set of 2,624 test records was compiled and curated, representing 990 unique mono-constituent substances, each tested at least twice. Conditional probabilities were used to evaluate the reproducibility of the in vivo method in identification of EPA or GHS hazard categories. Chemicals classified as moderate irritants at least once were classified as mild irritants or non-irritants at least 40% of the time when tested repeatedly. Variability was greatest between mild and moderate irritants, for which each type of substance had less than a 50% likelihood of its classification being replicated. This analysis indicates that variability of the rabbit skin irritation test should be considered when evaluating the performance of non-animal alternative methods as potential replacements. The analysis was used as a case study in a review (Alves et al. 2021) highlighting the importance of data curation in developing data sets used as inputs for artificial intelligence models.

### Variability analysis of in vivo acute oral systemic toxicity data

Tags: EPA, NIEHS, acute toxicity, oral toxicity

There is a pressing need to develop reliable and robust reference acute systemic toxicity data sets to contextualize results, to set expectations regarding NAM performance, and to train and evaluate computational models. To meet these needs, EPA and NICEATM compiled and curated rat acute oral LD50 data from multiple databases (Karmaus et al. 2022 (https://doi.org/10.1093/toxsci/kfac042)). More than 2,000 chemicals with LD50 values from at least two independently conducted rat acute oral systemic toxicity assays were subjected to comprehensive manual review to curate all data. Variability could not be attributed to any chemical-specific characteristics, and thus it was concluded that inherent biological or protocol variability is likely underlying the variance in the results. Understanding the challenges with reproducibility of the rat acute systemic toxicity test helps to better inform appropriate evaluation of future NAM performance assessments.

### Variability analysis of human skin sensitization data to use in establishing confidence for alternative methods

Tags: CPSC, FDA, NIEHS, skin sensitization

Because humans are the primary subject of interest for regulatory safety testing, it is advantageous to have human reference data available for evaluation of NAMs for assessing chemical safety. Scientists with CPSC, FDA, and NIEHS and collaborators compiled such a data set for human skin sensitization potential by collecting data from the scientific literature for human predictive patch tests that used the human maximization or human repeated insult patch test protocols. They then assessed the variability of these data to determine the potential impact on concordance with NAMs. The data collection identified 2,255 tests that were deemed to be sufficiently reliable for the analysis, including reports for 232 substances with at least two test results. The substances included anilines, amines, aldehydes, esters, and other chemical classes. For 68 substances, all tests were positive (at least one sensitized subject in a study); for 126 substances, all tests were negative (no sensitized subjects); and for the remaining 38 substances, both positive and negative results were obtained. None of the protocol variables such as test type, skin patch size, sample size, or dose applied were associated with high or low variability. There was also no detected association with variability for any of the 10 physicochemical properties examined. The effect of variation in vehicle used could not be analyzed because the majority of tests used a single vehicle. Future work will examine the variability of potency estimates, measured as the dose per skin area that sensitizes one subject. This characterization provides context for defining benchmarks for the evaluation of NAMs for skin sensitization assessments. A poster describing the data set (Strickland et al. (https://ntp.niehs.nih.gov/go/niceatm-sot22)) will be presented at the 2022 annual meeting of the Society of Toxicology.

### Implementation of ontologies for zebrafish developmental toxicity screening

Tags: DoD, EPA, NIEHS, developmental toxicity

Toxicological evaluation of chemicals using early life stage zebrafish (Danio rerio) involves the observation and recording of altered phenotypes. Variability has been observed among researchers in phenotypes reported from similar studies. This variation and a lack of consistent data annotation indicate a need for harmonization of both terminology and data. When examined from a data science perspective, many apparent differences can be parsed into the same or similar endpoints whose measurements differ only in time, methodology, or nomenclature. Standardized nomenclature systems known as ontologies can be leveraged to integrate diverse data sets. Building on this premise, the NTP’s Systematic Evaluation of the Application of Zebrafish in Toxicology program coordinated a collaborative exercise to evaluate how the application of standardized phenotype terminology improved data consistency (Thessen et al. 2022 (https://doi.org/10.3389/ftox.2022.817999)). Zebrafish researchers were asked to assess images of zebrafish larvae for morphological malformations in two surveys. In the first survey, researchers were asked to annotate observed malformations using their own terminology. In the second survey, researchers were asked to annotate the images from a list of terms and definitions from the Zebrafish Phenotype Ontology. Analysis of the results suggested that the use of ontology terms increased consistency and decreased ambiguity, and that utilizing a common data standard should reduce the heterogeneity of reported terms and potentially increase agreement and repeatability between different laboratories.

### Quantification of variance in data from systemic in vivo toxicology studies

Tags: EPA

NAMs for chemical hazard assessment are often evaluated in comparison to animal studies. However, variability in animal study data represents a barrier to an objective evaluation of NAM accuracy. Data available in EPA’s ToxRefDB enable consideration of such variability in effect levels, measured as the lowest effect level (LEL) for a treatment-related effect and the lowest observable adverse effect level (LOAEL) defined by expert review. These data are available from subacute, subchronic, chronic, and multi-generational reproductive and developmental toxicity studies. EPA scientists reviewed ToxRefDB data to quantify the variance within systemic LEL and LOAEL values and to estimate the upper limit of NAM prediction accuracy (Pham et al. 2020 (https://pubmed.ncbi.nlm.nih.gov/33426408/)). The analysis enabled both a quantification of the total variance in systemic LEL and LOAEL values and an estimate of the unexplained variance in LEL and LOAEL values. These findings suggest quantitative considerations for building scientific confidence in NAM-based systemic toxicity predictions.

### Relocation of ALTBIB to NTP website

Tags: NIEHS, NLM

ALTBIB (https://ntp.niehs.nih.gov/go/altbib) is the Bibliography on Alternatives to the Use of Live Vertebrates in Biomedical Research and Testing. The National Library of Medicine (NLM) developed ALTBIB to provide access to PubMed citations for users seeking information on alternatives to animal testing. Many citations provide access to free full text.

In December 2020, ALTBIB was revised and relocated to the NICEATM section of the NTP website. The search strategy on the new ALTBIB site was updated to capture key topics of current interest such as MPS and QSAR models. The content was reorganized to provide additional user support, and more links were added to the “Additional Resources” list. Users can still edit the ALTBIB search strategy to broaden or narrow searches. A list of keywords related to specific topics that was available on the NLM ALTBIB site is being updated and revised, and the list will be added back to the NICEATM website when that work is complete.

### Development of MPS-Db data portal

Tags: DoD, NIEHS, NIH, COVID-19, MPS

NICEATM and the UK National Centre for the 3Rs (NC3Rs) are partnering with the National Institute of Allergy and Infectious Diseases, the U.S. Army Combat Capabilities Development Command Chemical Biological Center, and NCATS to direct the MPS for COVID Research (MPSCoRe) working group. This group is coordinating the use of MPS to reduce animal use in studies of COVID-19 and future emerging infectious diseases.

One key activity of MPSCoRe is supporting the expansion of the MPS Database (MPS-Db) to include a COVID-19 disease portal (https://mps.csb.pitt.edu/diseases/covid-19/), which went live in April 2021. Through this portal, researchers can share experimental data, analytic tools, model designs, and study components to accelerate the development and adoption of human MPS for testing therapies and improving disease understanding. The portal has links to further information and resources to support the development and application of MPS that can recapitulate the pathophysiology of COVID-19 in various organ systems. Details of commercially available MPS, as well as components used in designing and implementing SARS-CoV-2/COVID-19 studies, have been uploaded to the platform to support access to existing MPS and the development of new models.

In the next phase of development of the MPS-Db, MPSCoRe members will upload and share their own COVID-19 MPS models and study data generated by them. Model details and data collected in the portal include model schematics, cell sources/types, key references, model variations, study designs, and assay data and associated metadata generated in response to various stimuli. The primary user can specify data access permissions so that other users of the database can access these data and use the in-built modeling capabilities to reanalyze them, maximizing the potential impact of each individual study. The development of the COVID-19 disease portal and the creation of a comprehensive centralized hub for COVID-19 infection and pathogenesis in the MPS-Db will potentially improve the speed and efficiency with which researchers obtain the information required to inform the design, development, and application of human MPS experimental models for therapeutic development.

### Annotation and visualization of high-throughput in vitro data

Tags: NIEHS, Tox21

Linking in vitro HTS data from programs such as ToxCast and Tox21 to regulatory endpoints remains a challenge and requires both detailed information about the assays and an understanding of their biological context. For example, while information may be provided about an in vitro assay’s technology platform, design, and gene target information, it remains a challenge to interpret this information in a toxicological context for potential regulatory applications. NICEATM scientists developed a mapping approach for HTS assay endpoints that provides a robust assay grouping schema applicable beyond HTS data sets in a toxicological endpoint-based framework. This expert-led curation and annotation is available in ICE (https://ice.ntp.niehs.nih.gov/) and is described in Abedini et al. 2021. The annotations map HTS assays to regulatory toxicological endpoints of interest through modes of action, which use structured vocabularies to allow data to be searched, grouped, and visualized. The annotations further increase accessibility for those unfamiliar with individual assays by defining mechanistic targets that provide context for in vitro assays to facilitate data interpretation. By leveraging these annotations, users of ICE can better identify data gaps, gain insight into mechanistic plausibility, and investigate endpoints of regulatory relevance. ICE also provides data visualization to aid review of a chemical’s potential activity based on selected mechanistic targets or modes of action contributing to regulatory endpoints.

## Tox21 Cross-partner Projects

Tox21 (https://tox21.gov/) is a collaboration among groups within four U.S. federal organizations aimed at developing more efficient approaches to predict how chemicals may affect human health. Tox21 studies use assays that are run at higher throughput than traditional tests. Test approaches developed and data collected via this initiative may enable agencies to reduce reliance on animal data for assessing chemical safety.

To more broadly address evolving challenges in toxicology, Tox21 partners developed a new strategic and operational plan (https://www.ncbi.nlm.nih.gov/pubmed/29529324) (Thomas et al. 2018 (https://doi.org/10.14573/altex.1803011)) that expands the focus of the program’s research activities. New areas of focus are:

- Develop alternative test systems that are predictive of human toxicity and dose response.
- Address key technical limitations of current in vitro test systems.
- Curate and characterize legacy in vivo toxicity studies.
- Establish scientific confidence in integrated assay batteries and in vitro test systems.
- Refine and deploy in vitro methods for characterizing pharmacokinetics and in vitro disposition.

The four groups participating in the Tox21 collaboration are ICCVAM members:

- U.S. Environmental Protection Agency
- U.S. Food and Drug Administration
- Division of the National Toxicology Program (within NIEHS)
- National Center for Advancing Translational Sciences (NCATS; within the National Institutes of Health)

Tox21 projects and projects using Tox21 data are described below and throughout this report (https://ntp.niehs.nih.gov/iccvamreport/2021/tags/?topic=Tox21).

### Predictive modeling of developmental toxicity with human pluripotent stem cells

Tags: EPA, FDA, NIEHS, developmental toxicity, IVIVE, stem cells, Tox21

EPA, FDA, and NICEATM scientists and collaborators applied IVIVE to evaluate the impact of pharmacokinetic models on predicting relevant external exposure from in vitro developmental toxicity potential concentrations derived from an in vitro human-induced pluripotent stem cell (iPSC)-based assay. Previous work showed that the devTOX quickPredict assay ranked the developmental toxicity potential of valproate analogues in a manner that was consistent with observed developmental toxicity potency in vivo. The IVIVE analysis in this project estimated equivalent administered doses that would result in maternal and fetal blood concentrations equivalent to the developmental toxicity potential and cytotoxic in vitro concentrations (Chang et al. 2022 (https://onlinelibrary.wiley.com/doi/10.1002/bdr2.2019)). The estimated equivalent administered doses were compared to published lowest effect levels from in vivo developmental toxicity studies. Preliminary results of this analysis showed that equivalent administered doses for the valproate analogues based on different pharmacokinetic and PBPK models were quantitatively similar to in vivo data from both rats and humans, where available. The impact of in vitro kinetics on equivalent administered dose estimates was chemical-dependent. Equivalent administered doses from this study were within the range of predicted doses from other in vitro and model organism data. This suggested that the devTOX quickPredict assay and IVIVE approaches can quantitatively assess a chemical’s developmental toxicity potential.

### Incorporating genetic susceptibility into developmental neurotoxicity screening via population diversity

Tags: EPA, FDA, NIEHS, developmental toxicity, neurotoxicity, Tox21

The potential for neurotoxicity in children following exposure to environmental chemicals is of concern due to recent increases in the prevalence of neurological disorders such as attention deficit hyperactivity disorder and autism. Neurotoxicity risk for an individual can be influenced both by genetic background and by exposures to neurotoxic chemicals in the environment. To investigate the role of genetic diversity in susceptibility to neurotoxicity, scientists at NIEHS, EPA, and FDA are using a genetically diverse set of cells to evaluate a curated set of chemicals with neurotoxic potential. Neural progenitor cells were derived from a set of mice bred to maximize genetic diversity. An initial set of 200 genetically different cell lines from male and female mice was narrowed down to 135 cell lines, considered to be the minimum number of cell lines needed to quantitatively assess diversity in population responses. The panel of cell lines was exposed to 8 concentrations of a 12-chemical test set. The intracellular morphometry of each treated cell was visualized using a high-content imaging assay called cell painting, which uses six fluorescent dyes to quantitatively describe cell features such as cell membranes, mitochondria, DNA and RNA, cytoskeleton, and Golgi bodies (Bray et al. 2016 (https://doi.org/10.1038/nprot.2016.105)). Data analysis is ongoing, and data will be used to derive PODs for chemical-induced intracellular morphometric endpoints and characterize the variability in these PODs across cell lines for each chemical. Data will also be analyzed to explore differences in toxicity mode of action that may differ across lines and therefore be genetically linked. These data will inform data-driven uncertainty factors that account for interindividual variability, allowing for adequate protection of genetically sensitive subpopulations. A poster describing the project (Harrill et al.) will be presented at the 2022 annual meeting of the Society of Toxicology, with a talk planned for an accepted symposium at the 2023 meeting. A paper describing the project is planned for submission in 2023.

### Automation of reference chemical generation

Tags: EPA, NIEHS, NIH, Tox21, endocrine disruptors, AOP

To use data generated by HTS initiatives such as Tox21 and ToxCast in regulatory applications, the assays and models built from the assays must be validated based on their performance against the biological targets they query. This requires developing sets of reference chemicals that consistently yield reproducible results when assayed for these biological targets. Furthermore, the development of reference chemical sets needs to be streamlined and rapid enough to manage the tens to hundreds of assays that can help inform regulatory toxicity endpoints. To address this need, scientists at EPA and NIEHS developed a process to identify reference chemicals that consistently produce positive or negative results when tested in defined assays (Judson et al. 2019 (https://www.ncbi.nlm.nih.gov/pmc/articles/PMC6784312/)). Work under this project conducted in partnership with NCATS seeks to automate the generation of reference chemical lists without the need for new experimental tests or upfront literature review. The targets being examined for this project are androgen receptor, estrogen receptor, glucocorticoid receptor, peroxisome proliferator-activated receptor gamma, progesterone receptor, retinoic acid receptors, thyroid hormone receptor, tumor protein P53, mitochondria toxicity, and cell stress pathways. The list of assays and reference chemicals generated through this process will be used to validate new assays or AOPs, which will improve chemical screening abilities when predicting toxicity. The project will be described in one or more papers to be submitted for publication in 2022 and 2023.

### Retrofitting existing Tox21 HTS assays with metabolic capability

Tags: EPA, NIEHS, NIH, Tox21

The HTS assays that have been run in the Tox21 testing program to date generally lack the metabolic activity found in living systems, which can potentially increase or decrease the toxicity of chemicals. As a result, HTS results may not accurately reflect in vivo activity.

Scientists at EPA, NCATS, and NIEHS are using several approaches to address this problem: adding human or rat liver microsomes into the existing assays, transfecting cells with mRNAs encoding human metabolic enzymes, or using metabolically capable human HepaRG cells. Work in 2020 and 2021 (Ooka et al. 2022 (https://pubmed.ncbi.nlm.nih.gov/35435491/)) focused on three types of assays for which data have already been generated: cellular stress-related assays, endocrine disruption assays, and CYP450 enzyme inhibition assays. The retrofitted assays were used to screen the Tox21 10K chemical library to identify chemicals that are either bioactivated or detoxified by metabolic activity.

### Expansion of pathway coverage by Tox21 HTS assays for better prediction of adverse drug effects

Tags: NIEHS, FDA, NIH, Tox21, hepatotoxicity, cardiotoxicity, AOP

To date, Tox21 HTS assays have focused primarily on selected nuclear receptor and stress response pathways. This relatively limited focus suggests that activity in other toxicity pathways has not been adequately assessed; it is likely that some unexplored pathways relate to unanticipated adverse drug effects. Therefore, expanding the coverage of biological responses by adding assays that probe under-represented pathways in the current Tox21 assay portfolio may improve the predictivity of Tox21 data. Scientists at FDA, NIEHS, and NCATS are systematically identifying these under-represented pathways in a data-driven approach and nominating assays for development and Tox21 chemical screening. The data generated will be used to build models for human toxicity prediction, focusing on common adverse drug effects such as drug-induced liver injury and cardiotoxicity. The initial survey identified targets and pathways of interest, including cytochrome P450 metabolic enzymes and G protein-coupled receptors. HTS assays were optimized and validated for the proposed new targets and pathways, and these assays will be used to screen the Tox21 10K chemical library in 2022. Models are being built that could use HTS assay data to predict human toxicity. Predictions from the models will be validated in relevant assays. A paper describing the project and the prediction models will be prepared in late 2022.

### Profiling activity of acetylcholinesterase inhibitors

Tags: EPA, FDA, NIEHS, NIH, neurotoxicity, Tox21

Acetylcholinesterase inhibitors cause a variety of adverse effects in the nervous system. Some acetylcholinesterase inhibitors serve as drugs, while others are used as pesticides or found in natural products. Scientists at FDA, NIEHS, and NCATS and collaborators developed acetylcholinesterase inhibition assays (Li et al. 2017 (https://www.ncbi.nlm.nih.gov/pubmed/28294544), 2019 (https://www.ncbi.nlm.nih.gov/pubmed/30625376)). These assays were then used to screen the Tox21 10K chemical library to identify environmental chemicals that inhibit acetylcholinesterase activity (Li et al. 2021). The screening study, which included NIEHS scientists and other collaborators, identified both known and not previously reported acetylcholinesterase inhibitors, which were further characterized in lower-throughput cell-based assays, enzyme-based activity assays, and molecular docking studies. Specifically, this study identified 18 potential novel acetylcholinesterase inhibitors, most of them clinically approved drugs. Cmax values, which represent the highest concentration of a drug in the blood or target organ after a dose, were found from the literature for 14 drugs. These were compared with half-maximal inhibitory concentration (IC50) values generated from this study (Santillo and Xia, 2022 (https://pubmed.ncbi.nlm.nih.gov/35058177/)). The ratio of IC50 and Cmax can be used to prioritize the compounds for further study. This represents a robust and reliable approach to evaluating large sets of environmental compounds for their acetylcholinesterase inhibitory activity.

### Development of high-throughput assays to detect potential sensitizers or irritants

Tags: NIEHS, NIH, skin irritation, skin sensitization, Tox21

Assessing the sensitization or irritation potential is a key element in the safety evaluation of topically applied or exposed chemicals and drugs. European legislation now mandates the use of alternative test methods for these compounds, instead of testing them on animals. Developing HTS assays for these compounds would provide a faster and cheaper alternative testing method than current in vitro assays. Scientists from NIEHS and NCATS collaborated to explore development of HTS approaches to identify potential irritants and sensitizers. Studies described in a 2020 publication (Wei et al. 2020) found that HTS-compatible 2D cellular and 3D tissue skin models could be combined with irritation-relevant activity endpoints to assess the irritation effects of topical-use compounds and identify potential hazards. To identify potential skin sensitizers, the Tox21 10K compound library was screened for potential sensitizers using the KeratinoSens assay. Substances identified as active were further tested using a high-throughput version of the direct peptide reactivity assay (Wei et al. 2021 (https://doi.org/10.1016/j.toxlet.2020.12.002)), an interleukin-8 assay, and the human cell line activation test. Analysis of these data are ongoing, and the results will be reported in a paper to be published in 2022.

### Predictive toxicology of the retinoid signaling pathway

Tags: EPA, FDA, NIEHS, NIH, AOP, developmental toxicity, IVIVE, Tox21

The developing child is vulnerable to genetic, pharmacological, or chemical disruption of the retinoid biochemical pathway, especially during early growth and differentiation of embryonic tissues. Susceptibility of this pathway to chemical disruption is an important regulatory concern for developmental and reproductive hazard identification. In this study, which involves all four Tox21 participating offices, Tox21 data are being mined and modeled to identify potential retinoid pathway disruptors. Results from a dozen Tox21 molecular targets mapping to retinoid pathway targets identified over 100 structurally diverse chemicals with relevant bioactivity. Computational tools and approaches are now being built to integrate these data with embryological knowledge and construct data-driven models for developmental hazard prediction. For example, a computational model that linked chemical disruption of the retinoic acid signaling pathway with fetal skeletal defects has been aligned with a provisional AOP framework for craniofacial, vertebral, and/or appendicular phenotypes (Knudsen et al. 2021; Pierro et al. submitted). Papers in preparation related to this project describe the use of these data as input for IVIVE models to predict relevant exposure levels and to develop candidate reference chemicals for in vitro retinoid pathway assays. Participants in the project contributed to a “Detailed Review Paper on the Retinoid System (https://www.oecd.org/officialdocuments/publicdisplaydocumentpdf/?cote=ENV-CBC-MONO(2021)20%20&doclanguage=en)” issued by OECD in 2021, and described findings in a poster presented at the 2021 annual meeting of the Society of Toxicology (Pierro et al.), a platform presentation at the 2021 annual meeting of the Society for Birth Defects Research and Prevention (Pierro et al.), and a workshop session at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences (Knudsen et al. 2021).

### Investigation of environmental determinants of pubertal timing in girls

Tags: NIH, NIEHS, endocrine disruptors, Tox21

Over the past decade, there has been a worldwide trend toward earlier breast development in girls. The rapid pace of this trend suggests the involvement of environmental factors. While some studies (e.g., Bandera et al. 2011 (https://doi.org/10.1016/j.scitotenv.2011.09.029)) have suggested a relationship between the presence of endocrine-disrupting chemicals in girls and pubertal timing, more evidence is needed to develop clear associations. Scientists at NIEHS and NCATS are examining the potential effects of endocrine-disrupting chemicals on important components of the biochemical pathway responsible for pubertal timing. Chemicals in the Tox21 10K collection are being tested in human cell-based assays that measure activation or inhibition of the gonadotropin-releasing hormone receptor and kisspeptin receptor. These receptors are expressed in the hypothalamus and are important players in the control of pubertal timing. Chemicals that exhibit activity will be tested further in cell-based assays or possibly in animals to confirm the biological relevance of the identified activity and determine the chemical’s mechanism of action.