# Reference Pages

## Agency Representatives in 2020 and 2021

Tags: ICCVAM

The individuals listed on this page served as representatives from ICCVAM member agencies in 2020 and 2021. ICCVAM includes three types of representatives:

- The Principal Agency Representative is the primary source of communication from his or her agency to the committee and NICEATM. He or she regularly attends all ICCVAM meetings and teleconferences, coordinates participation of other representatives from the agency, and casts the agency’s vote on occasions when formal voting is required.
- Alternate Agency Representatives participate in ICCVAM committee activities in place of the Principal when necessary.
- An agency may designate one or more Other Agency Representatives to participate in ICCVAM to provide broader representation or expertise.

Agency (Office) | Representative | Representative Type (as of December 2021) | Service Continuing into 2022
Agency for Toxic Substances and Disease Registry | Moiz Mumtaz, M.Sc., Ph.D. | Principal | Yes
Agency for Toxic Substances and Disease Registry | Patricia Ruiz, Ph.D.. | Alternate | Yes
National Cancer Institute | Brian Cholewa, Ph.D. | Principal | Yes
National Cancer Institute | Mark Miller, Ph.D., FAC-COR III | Other | -
National Cancer Institute | Ron Johnson, Ph.D. | Alternate | Yes
National Institute for Occupational Safety and Health | Richard Probst, D.V.M., M.P.H., DACLAM, DACPVM | Principal | Yes
National Institute of Environmental Health Sciences | Brian Berridge, D.V.M., Ph.D., D.A.C.V.P. | Principal | Yes
National Institute of Environmental Health Sciences | Mamta Behl, Ph.D., D.A.B.T. | Other | -
National Institute of Environmental Health Sciences | Stephen Ferguson, Ph.D. | Alternate | Yes
National Institute of Environmental Health Sciences | Warren Casey, Ph.D., D.A.B.T. | Other | Yes
National Institute of Environmental Health Sciences | Nicole Kleinstreuer, Ph.D. | Other | Yes
National Institute of Environmental Health Sciences | Elizabeth Maull, Ph.D. | Other | -
National Institute of Standards and Technology | John Elliott, Ph.D. | Principal | Yes
National Institute of Standards and Technology | Elijah Petersen, Ph.D. | Alternate | Yes
National Institutes of Health | Harold Watson, Ph.D. | Other | -
National Library of Medicine | Pertti (Bert) Hakkinen, Ph.D. | Other | -
National Library of Medicine | Jeanne Goshorn, M.S. | Principal | Yes
Occupational Safety and Health Administration | Surender Ahir, Ph.D. | Other | -
Occupational Safety and Health Administration | Janet Carter | Alternate | Yes
Occupational Safety and Health Administration | Deana Holmes, M.T. | Principal | Yes
U.S. Consumer Product Safety Commission | John Gordon, Ph.D. | Principal | Yes
U.S. Consumer Product Safety Commission | Kristina Hatlelid, Ph.D. | Alternate | Yes
U.S. Consumer Product Safety Commission | Eric Hooker, M.S. | Alternate | Yes
U.S. Consumer Product Safety Commission | Joanna Matheson, Ph.D. | Alternate | Yes
U.S. Department of Agriculture | Carol Clarke, D.V.M., DACLAM | Principal | Yes
U.S. Department of Agriculture | Kristina Adams, M.S. | Alternate | Yes
U.S. Department of Agriculture | Erika Edwards | Other | Yes
U.S. Department of Agriculture | Aisha Ellis, D.V.M. | Other | Yes
U.S. Department of Agriculture | Ben Green, Ph.D. | Other | Yes
U.S. Department of Agriculture | Katherine Horak, Ph.D. | Other | Yes
U.S. Department of Agriculture | Patrice Klein, M.S., V.M.D., DACPV, DACVPM | Other | Yes
U.S. Department of Agriculture | Jessie Kull | Other | Yes
U.S. Department of Defense | Matthew Johnson, D.V.M., DACLAM | Alternate (acting Principal) | Yes
U.S. Department of Defense | Emily N. Reinke, Ph.D., D.A.B.T. (Co-chair) | Alternate | Yes
U.S. Department of Energy | Prem C. Srivastava, Ph.D. | Principal | -
U.S. Department of the Interior | Barnett A. Rattner, Ph.D. | Principal | Yes
U.S. Department of the Interior | Jessica Leet, Ph.D. | Alternate | Yes
U.S. Department of the Interior | Tim Bargar, Ph.D. | Other | Yes
U.S. Department of the Interior | Adria Elskus, Ph.D. | Other | -
U.S. Department of the Interior | Paula F.P. Henry, Ph.D. | Other | Yes
U.S. Department of the Interior | Luke R. Iwanowicz, Ph.D. | Other | Yes
U.S. Department of Transportation | Steve Hwang, Ph.D. | Principal | Yes
U.S. Department of Transportation | Ryan Vierling, Ph.D. | Alternate | Yes
U.S. Department of Veterans Affairs Office of Research and Development | Christopher Bever, M.D., MBA | Principal | Yes
U.S. Department of Veterans Affairs Office of Research and Development | Holly Krull, Ph.D. | Alternate | Yes
U.S. Department of Veterans Affairs Office of Research and Development | George Lathrop, D.V.M., M.S., DACLAM | Other | Yes
U.S. Department of Veterans Affairs Office of Research and Development | Mario Rinaudo, M.D. | Other | -
U.S. Environmental Protection Agency (Office of Pesticide Programs) | Anna Lowit, Ph.D. (Co-chair) | Principal | Yes
U.S. Environmental Protection Agency (Office of Pollution Prevention and Toxics) | Louis (Gino) Scarano, Ph.D. | Other | Yes
U.S. Environmental Protection Agency (Office of Research and Development) | Pamela Noyes, Ph.D. | Alternate | Yes
U.S. Environmental Protection Agency (Office of Research and Development) | Stephanie Padilla, Ph.D. | Alternate | Yes
U.S. Food and Drug Administration (Center for Biologics Evaluation and Research) | Robin Levis, Ph.D. | Other | Yes
U.S. Food and Drug Administration (Center for Biologics Evaluation and Research) | Allen Wensky, Ph.D. | Other | Yes
U.S. Food and Drug Administration (Center for Devices and Radiological Health) | Simona Bancos, Ph.D. | Other | Yes
U.S. Food and Drug Administration (Center for Devices and Radiological Health) | Jennifer Goode | Alternate | Yes
U.S. Food and Drug Administration (Center for Devices and Radiological Health) | Rakhi Dalal-Panguluri, Ph.D. | Other | Yes
U.S. Food and Drug Administration (Center for Drug Evaluation and Research) | Paul C. Brown, Ph.D. | Other | Yes
U.S. Food and Drug Administration (Center for Drug Evaluation and Research) | Jill Merrill, Ph.D. | Other | Yes
U.S. Food and Drug Administration (Center for Food Safety and Applied Nutrition) | Patrick Crittenden, Ph.D. | Other | Yes
U.S. Food and Drug Administration (Center for Food Safety and Applied Nutrition) | Suzanne Fitzpatrick, Ph.D., D.A.B.T. | Principal | Yes
U.S. Food and Drug Administration (Center for Tobacco Products) | Jueichuan (Connie) Kang, Ph.D. | Other | Yes
U.S. Food and Drug Administration (Center for Veterinary Medicine) | M. Cecilia Aguila, D.V.M. | Other | Yes
U.S. Food and Drug Administration (Center for Veterinary Medicine) | Li You, Ph.D. | Other | Yes
U.S. Food and Drug Administration (National Center for Toxicological Research) | Donna Mendrick, Ph.D. | Other | Yes
U.S. Food and Drug Administration (National Center for Toxicological Research) | Mugimane (Manju) Manjanatha, Ph.D. | Other | Yes
U.S. Food and Drug Administration (Office of the Chief Scientist) | Tracy Chen, Ph.D., D.A.B.T. | Other | Yes
U.S. National Coordinator for OECD Test Guidelines Programme | Wanda Hall | Other
U.S. National Coordinator for OECD Test Guidelines Programme | Charles Kovatch | Other | Yes

## NICEATM and ICCVAM Publications, 2020-2021

This page lists publications issued in 2020 and 2021 that describe NICEATM and ICCVAM activities.

### NICEATM and ICCVAM reports

Tags: ICCVAM, NIEHS, eye irritation, IATA, metrics, mixtures toxicity, skin sensitization

ICCVAM. 2020. Biennial Progress Report 2018-2019 [Internet]. Research Triangle Park (NC): National Institute of Environmental Health Sciences [cited 17 February 2022]. Available: https://ntp.niehs.nih.gov/iccvamreport/2019/index.html.
ICCVAM. 2021. Measuring U.S. Federal Agency Progress Toward Implementation of Alternative Methods in Toxicity Testing [Internet]. Research Triangle Park (NC): National Institute of Environmental Health Sciences [cited 17 February 2022]. Available: https://ntp.niehs.nih.gov/iccvam/docs/about_docs/iccvam-measuringprogress-feb2021-fd-508.pdf.
NIEHS. 2020. Application of Non-animal Test Methods and Defined Approaches to Skin Sensitization Assessment of Isothiazolinone Compounds [Internet]. Research Triangle Park (NC): National Institute of Environmental Health Sciences [cited 17 February 2022]. Available: https://ntp.niehs.nih.gov/iccvam/methods/immunotox/it/niceatm-it-report-june2020-final-wappx-508.pdf (https://ntp/).
NIEHS. 2021. Prospective and Retrospective Evaluation of the Eye Irritation Potential of Agrochemical Formulations [Internet]. Research Triangle Park (NC): National Institute of Environmental Health Sciences [cited 17 February 2022]. Available: https://ntp.niehs.nih.gov/iccvam/docs/ocutox_docs/formulationreport_2021_fd-508.pdf.

### Federal Register notices

Tags: ICCVAM, NIEHS, mixtures toxicity, developmental toxicity, neurotoxicity

All Federal Register notices issued by NICEATM can be found on the NTP website at http://ntp.niehs.nih.gov/go/frn.

NIEHS. 2020. ICCVAM notice of public webcast; request for public input. Federal Register. 85(74): 21256–21257.
NIEHS. 2020. ICCVAM Biennial Progress Report: 2018-2019; availability of report. Federal Register. 85(137): 43249–43240.
NIEHS. 2021. ICCVAM Communities of Practice Webinar on Non-animal Approaches for Mixtures Assessment. Federal Register. 86(6): 1981–1982.
NIEHS. 2021. ICCVAM notice of public webcast; request for public input. Federal Register. 86(67): 18547–18548.
NIEHS. 2021. Request for data and information on new approach methodologies for efficacy testing of ectoparasiticide products to meet regulatory data requirements. Federal Register. 86(242): 72251.
NIEHS. 2021. ICCVAM Communities of Practice Webinar on New Approach Methodologies to Assess (Developmental) Neurotoxicity. Federal Register. 86(243): 72609–72610.

### Journal articles

A full list of NICEATM and ICCVAM publications is available on the NTP website (https://ntp.niehs.nih.gov/go/niceatm-pubs).

Abedini JA, Cook B, Bell S, Chang X, Choksi N, Daniel AB, Hines D, Karmaus AL, Mansouri K, McAfee E, Phillips J, Rooney J, Sprankle CS, Allen D, Casey W, Kleinstreuer N. 2021. Application of new approach methodologies: ICE tools to support chemical evaluations. Comput Toxicol 20:100184. 10.1016/j.comtox.2021.100184.
Allen D, Rooney J, Kleinstreuer N, Lowit A, Perron M. 2021. Retrospective analysis of dermal absorption triple pack data. ALTEX 38(3):463–476. 10.14573/altex.2101121.33712859
Alves VM, Auerbach SS, Kleinstreuer NC, Rooney JP, Muratov EN, Rusyn I, Tropsha A, Schmitt C. 2021. Curated data in — trustworthy in silico models out: the impact of data quality on the reliability of artificial intelligence models as alternatives to animal testing. ATLA 49(3):73–82. 10.1177/02611929211029635.34233495
Bassan A, Alves V, Amberg A, Anger LT, Auerbach S, Beilke L, Bender A, Cronin MTD, Cross KP, Hsieh JH, Greene N, Kemper R, Kim MT, Mumtaz M, Noeske T, Pavan M, Pletz J, Russo DP, Sabnis Y, Schaefer M, Szabo DT, Valentin JP, Wichard J, Williams D, Wooley D, Zwickl C, Myatt GJ. 2021. In silico approaches in organ toxicity hazard assessment: Current status and future needs in predicting liver toxicity. Comput Toxicol 20:100187. 10.1016/j.comtox.2021.100187.35340402
Bassan A, Alves V, Amberg A, Anger LT, Beilke L, Bender A, Bernal A, Cronin MTD, Hsieh JH, Johnson C, Kemper R, Mumtaz M, Nielson L, Pavan M, Pointon A, Pletz J, Ruiz P, Russo DP, Sabnis Y, Sandhu R, Schaefer M, Stavitskaya L, Szabo DT, Valentin JP, Wooley D, Zwickl C, Myatt GJ. 2021. In silico approaches in organ toxicity hazard assessment: Current status and future needs for predicting heart, kidney and lung toxicities. Comput Toxicol 20:100188. 10.1016/j.comtox.2021.100188.35721273
Bell S, Abedini J, Ceger P, Chang X, Cook B, Karmaus AL, Lea I, Mansouri K, Phillips J, McAfee E, Rai R, Rooney J, Sprankle C, Tandon A, Allen D, Casey W, Kleinstreuer N. 2020. An integrated chemical environment with tools for chemical safety testing. Toxicol In Vitro 67:104916. 10.1016/j.tiv.2020.104916.32553663
Borba J, Braga RC, Alves VM, Muratov EN, Kleinstreuer NC, Tropsha A, Andrade CH. 2021. Pred-Skin: A web portal for accurate prediction of human skin sensitizers. Chem Res Toxicol 34(2):258–267. 10.1021/acs.chemrestox.0c00186.32673477
Borrel A, Auerbach S, Houck KA, Kleinstreuer NC. 2020. Tox21BodyMap: a webtool to map chemical effects on the human body. Nucleic Acids Res 48(W1):W472–W476. 10.1093/nar/gkaa433.32491175
Intramural Paper of the Month, NIEHS Environmental Factor August 2020 (https://factor.niehs.nih.gov/2020/8/papers/dir/index.htm).
Borrel A, Huang R, Sakamuru S, Xia M, Simeonov A, Mansouri K, Houck KA, Judson RS, Kleinstreuer NC. 2020. High-throughput screening to predict chemical-assay interference. Sci Rep 10:3986. 10.1038/s41598-020-60747-3.32132587
Borrel A, Mansouri K, Nolte S, Saddler T, Conway M, Schmitt C, Kleinstreuer NC. 2020. InterPred: a webtool to predict chemical autofluorescence and luminescence interference. Nucleic Acids Res 48(W1):W586–W590. 10.1093/nar/gkaa378.32421835
Brown J, Clippinger AJ, Briglia CF, Casey W, Coleman K, Fritsch A, Hartung T, Maouyo D, Muller T, Reich J, Robert L, Roeder R, Sanchez G, Sawyer AY, Solati S, Tirumalai R, Zwisler W, Allen D. 2021. Using the monocyte activation test as a stand-alone release test for medical devices. ALTEX 38(1):151–156. 10.14573/altex.2012021.33452530
Choksi N, Lebrun S, Nguyen M, Daniel A, DeGeorge G, Willoughby J, Layton A, Lowther D, Merrill J, Matheson J, Barroso J, Yozzo K, Casey W, Allen D. 2020. Validation of the OptiSafe™ eye irritation test. Cutan Ocul Toxicol 39(3):180–192. 10.1080/15569527.2020.1787431.32586141
Paper of the Year (2020), Society of Toxicology Ocular Toxicity Specialty Section.
Clippinger AJ, Raabe HA, Allen DG, Choksi N, van der Zalm A, Kleinstreuer N, Barroso J, Lowit AB. 2021. Human-relevant approaches to assess eye corrosion/irritation potential of agrochemical formulations. Cutan Ocul Toxicol 40(2):145–167. 10.1080/15569527.2021.1910291.33830843
Comess S, Akbay A, Vasiliou M, Hines RN, Joppa L, Vasiliou V, Kleinstreuer N. 2020. Bringing big data to bear in environmental health: challenges and recommendations. Front Artif Intell 3:31. 10.3389/frai.2020.00031.33184612
Eskes C, Casati S, Kleinstreuer N, Ezendam J. 2021. Usefulness and applicability of integrated strategy approaches in toxicology. Appl In Vitro Toxicol 7(3):89–90. 10.1089/aivt.2021.0021.
Groff K, Allen D, Casey W, Clippinger A. 2020. Increasing the use of animal-free recombinant antibodies. ALTEX 37(2):309–311. 10.14573/altex.2001071.31923318
Hagstrom A, Anastas P, Boissevain A, Borrel A, Deziel N, Fenton S, Fields C, Fortner J, Franceschi-Hofmann N, Frigon R, Jin L, Kim JH, Kleinstreuer N, Koelmel J, Lei Y, Liew Z, Ma X, Mathieu L, Nason S, Organtini K, Oulhote Y, Pociu S, Godri Pollitt K, Saiers J, Thompson D, Toal B, Weiner E, Whirledge S, Zhang Y, Vasiliou V. 2021. Yale School of Public Health Symposium: An overview of the challenges and opportunities associated with per- and polyfluoroalkyl substances (PFAS). Sci Total Environ 778:146192. 10.1016/j.scitotenv.2021.146192.33714836
Hamm J, Allen D, Ceger P, Flint T, Lowit A, O’Dell L, Tao J, Kleinstreuer N. 2021. Performance of the GHS Mixtures Equation for predicting acute oral toxicity. Reg Toxicol Pharmacol. 10.1016/j.yrtph.2021.105007.
Jain S, Siramshetty VB, Alves VN, Muratov EN, Kleinstreuer NC, Tropsha A, Nicklaus MC, Simeonov N, Zakharov AV. 2021. Large-scale modeling of multispecies acute toxicity end points using consensus of multitask deep learning methods. J Chem Inf Modeling 61(2):653–663. 10.1021/acs.jcim.0c01164.
Judson R, Houck K, Paul Friedman K, Brown J, Browne P, Johnston PA, Close DA, Mansouri K, Kleinstreuer N. 2020. Selecting a minimal set of androgen receptor assays for screening chemicals. Reg Toxicol Pharmacol 117:104764. 10.1016/j.yrtph.2020.104764.
Kleinstreuer N, Holmes A. 2021. Harnessing the power of microphysiological systems for COVID-19 research. Drug Discov Today 26(11):2496–2501. 10.1016/j.drudis.2021.06.020.34332095
Kleinstreuer NC, Tong W, Tetko IV. 2020. Computational toxicology [Editorial]. Chem Res Toxicol 33(3):687–688. 10.1021/acs.chemrestox.0c00070.32172570
Knudsen TB, Fitzpatrick SC, De Abrew KN, Birnbaum LS, Chappelle A, Daston GP, Dolinoy DC, Elder A, Euling S, Faustman EM, Fedinick KP, Fransoza JA, Haggard DE, Haws L, Kleinstreuer N, Louis GMB, Mendrick DL, Rudel R, Saili KS, Schug TT, Tanguay RL, Turley AE, Wetmore BA, White KW, Zurlinden TJ. 2021. FutureTox IV workshop summary: Predictive Toxicology for Healthy Children. Toxicol Sci 180(2):198–211. 10.1093/toxsci/kfab013.33555348
Krishna S, Berridge B, Kleinstreuer NC. 2021. High-throughput screening to identify chemical cardiotoxic potential. Chem Res Toxicol 34(2):566–583. 10.1021/acs.chemrestox.0c00382.33346635
Li X, Kleinstreuer NC, Fourches D. 2020. Hierarchical quantitative and structure–activity relationship modeling approach for integrating binary, multiclass, and regression models of acute oral systemic toxicity. Chem Res Toxicol 33(2):353–366. 10.1021/acs.chemrestox.9b00259.31975586
Mansouri K, Karmaus AL, Fitzpatrick J, Patlewicz G, Pradeep P, Alberga D, Alepee N, Allen THE, Allen DG, Alves VM, Andrade CH, Auernhammer TR, Ballabio D, Bell S, Benfenati E, Bhattacharya S, Bastos JV, Boyd S, Brown JB, Capuzzi SJ, Chushak Y, Ciallella H, Clark AM, Consonni V, Daga PR, Ekins S, Farag S, Fedorov M, Fourches D, Gadaleta D, Gao F, Gearhart JM, Goh G, Goodman JM, Grisoni F, Grulke CM, Hartung T, Hirn M, Karpov P, Korotcov A, Lavado GJ, Lawless M, Li X, Luechtefeld T, Lunghini F, Mangiatordi GF, Marcou G, Marsh D, Martin T, Mauri A, Muratov EN, Myatt GJ, Nguyen DT, Nicolotti O, Note R, Pande P, Parks AK, Peryea T, Polash AH, Rallo R, Roncaglioni A, Rowlands C, Ruiz P, Russo DP, Sayed A, Sayre R, Sheils T, Siegel C, Silva AC, Simeonov A, Sosnin S, Southall N, Strickland J, Tang Y, Teppen B, Tetko IV, Thomas D, Tkachenko V, Todeschini R, Toma C, Tripodi I, Trisciuzzi D, Tropsha A, Varnek A, Vukovic K, Wang Z, Wang L, Waters KM, Wedlake AJ, Wijeyesakere SJ, Wilson D, Xiao Z, Yang H, Zahoranszky-Kohalmi G, Zakharov AV, Zhang FF, Zhang Z, Zhao T, Zhu H, Zorn KM, Casey W, Kleinstreuer NC. 2021. CATMoS: Collaborative Acute Toxicity Modeling Suite. Environ Health Perspect 129:47013. 10.1289/EHP8495.33929906
Mansouri K, Kleinstreuer N, Abdelaziz AM, Alberga D, Alves VM, Andersson PL, Andrade CH, Bai F, Balabin I, Ballabio D, Benfenati E, Bhhatari B, Boyer S, Chen J, Consonni V, Farag S, Fourches D, Garcia-Sosa AT, Gramatica P, Grisoni F, Grulke CM, Hong H, Horvath D, Hu X, Huang R, Jeliazkova N, Li J, Li X, Liu H, Manganelli S, Mangiatordi GF, Maran U, Marcou G, Martin T, Muratov E, Nguyen DT, Nicolotti O, Nikolov NG, Norinder U, Papa E, Petitjean M, Piir G, Pogodin P, Poroikov V, Qiao X, Richard AR, Roncaglioni A, Ruiz P, Rupakheti C, Sakkiah S, Sangion A, Schramm KW, Selvaraj C, Shah I, Sild S, Sun L, Taboureau O, Tang Y, Tetko IV, Todeschini R, Tong W, Trisciuzzi D, Tropsha A, Ven Den Driessche G, Varnek A, Wang Z, Wedebye EB, Williams A, Xie H, Zakharov AV, Zheng Z, Judson RS. 2020. CoMPARA: Collaborative Modeling Project for Androgen Receptor Activity. Environ Health Perspect 128(2):027002. 10.1289/EHP5580.32074470
Nelms MD, Karmaus AL, Patlewicz G. 2020. An evaluation of the performance of selected (Q)SARs/expert systems for predicting acute oral toxicity. Comput Toxicol 16:100135. 10.1016/j.comtox.2020.100135.33163737
Pamies D, Leist M, Coecke S, Bowe G, Allen DG, Gstraunthaler G, Bal-Price A, Pistollato F, de Vries RBM, Hogberg HT, Hartung T, Stacey G. 2021. Guidance document on good cell and tissue culture practice 2.0. ALTEX 39(1):30–70. 10.14573/altex.2111011.34882777
Parish ST, Aschner M, Casey W, Corvaro M, Embry MR, Fitzpatrick S, Kidd D, Kleinstreuer NC, Lima BS, Settivari RS, Wolf DC, Yamazaki D, Boobis A. 2020. An evaluation framework for new approach methodologies (NAMs) for human health safety assessment. Reg Toxicol Pharmacol 112:104592. 10.1016/j.yrtph.2020.104592.
Patel V, Amin K, Allen D, Ukishima L, Wahab A, Grodi C, Behrsing H. 2021. Comparison of long-term human precision-cut lung slice culture methodology and response to challenge: an argument for standardization. Altern Lab Anim 49(5):209–222. 10.1177/02611929211061884.34836458
Petersen EJ, Ceger P, Allen DG, Coyle J, Derk R, Garcia-Reyero N, Gordon J, Kleinstreuer N, Matheson J, McShan D, Nelson BC, Patri AK, Rice P, Rojanasakul L, Sasidharan A, Scarano L, Chang X. 2021. U.S. federal agency interests and key considerations for new approach methodologies for nanomaterials. ALTEX 39(2):183–206. 10.14573/altex.2105041.34874455
Petersen E, Nguyen A, Brown J, Elliot J, Clippinger A, Gordon J, Kleinstreuer N, Roesslein M. 2021. Characteristics to consider when selecting a positive control material for an in vitro assay. ALTEX 38(2):365–376. 10.14573/altex.2102111.33637998
Petersen E, Sharma M, Clippinger A, Gordon J, Katz A, Laux P, Leibrock LB, Luch A, Matheson J, Stucki AO, Tentschert J, Bierkandt FS. 2021. Use of cause-and-effect analysis to optimize the reliability of in vitro inhalation toxicity measurements using an air–liquid interface. Chem Res Toxicol 34(6):1370–1385. 10.1021/acs.chemrestox.1c00080.34097823
Prior H, Baldrick P, Beken S, Booler S, Bower N, Brooker P, Brown P, Burlinson B, Burns-Naas LA, Casey W, Chapman M, Clarke D, de Haan L, Doehr O, Downes N, Flaherty M, Gellatly N, Moesgaard SG, Harris J, Holbrook M, Hui J, Jones D, Jones K, Kedar H, Mahl A, Manninen A, McGuire A, Mortimer-Cassen E, Peraza M, Pugsley MK, Richard J, Roberts R, Roosen W, Rothfuss A, Schoenmakers A, Sewell F, Weaver R, Weir L, Wolfreys A, Kimber I. 2020. Opportunities for use of one species for longer-term toxicology testing during drug development: A cross-industry evaluation. Reg Toxicol Pharmacol 113:104624. 10.1016/j.yrtph.2020.104624.
Richard AM, Huang R, Waidyanatha S, Shinn P, Collins BJ, Thillaindarajah I, Grulke CM, Williams AJ, Lougee RR, Judson RS, Houck KE, Shobair M, Yang C, Rathman JF, Yasgar A, Fitzpatrick SC, Simeonov A, Thomas RS, Crofton KM, Paules RS, Bucher JR, Austin CP, Kavlock RJ, Tice RR. 2021. The Tox21 compound library: collaborative chemistry advancing toxicology. Chem Res Toxicol 34(2):189–216. 10.1021/acs.chemrestox.0c00264.33140634
Rooney JP, Choksi NY, Ceger P, Daniel AB, Truax J, Allen DG, Kleinstreuer NC. 2021. Analysis of variability in the rabbit skin irritation assay. Regul Toxicol Pharmacol 122:104920. 10.1016/j.yrtph.2021.104920.33757807
Rovida C, Barton-Maclaren T, Benfenati E, Caloni F, Chandrasekera C, Chesne C, Cronin MTD, De Knecht J, Dietrich DR, Escher SE, Fitzpatrick S, Flannery B, Herzler M, Hougaard Bennekou S, Hubesch B, Kamp H, Kisitu J, Kleinstreuer N, Kovarich S, Leist M, Maertens A, Nugent K, Pallocca G, Pastor M, Patlewicz G, Pavan M, Presgrave O, Smirnova L, Schwarz M, Yamada T, Hartung T. 2020. Internationalization of read-across as a validation new approach method (NAM) for regulatory toxicology. ALTEX 37(4):579–606. 10.14573/altex.1912181.32369604
Sedykh AY, Shah RR, Kleinstreuer NC, Auerbach SS, Gombar VK. 2021. Saagar–a new, extensible set of molecular substructures for QSAR/QSPR and read-across predictions. Chem Res Toxicol 34(2):634–640. 10.1021/acs.chemrestox.0c00464.33356152
Smith MT, Guyton KZ, Kleinstreuer N, Borrel A, Cardenas A, Chiu WA, Felsher DW, Gibbons CF, Goodson WH, Houck KA, Kane AB, La Merrill MA, Lebrec H, Lowe L, McHale CM, Minocherhomji S, Rieswijk L, Sandy MS, Sone H, Wang A, Zhang L, Zeise L, Fielden M. 2020. The key characteristics of carcinogens: relationship to the hallmarks of cancer, relevant biomarkers, and assays to measure them. Cancer Epidemiol Biomarkers Prev 29:1887–1903. 10.1158/1055-9965.epi-19-1346.32152214
Sullivan K, Allen DG, Clippinger AJ, Wilson DM, Edwards SW, Glover K, Mansouri K, Settivari R, Wijeyesakere S, Casey W. 2021. Mind the gaps: prioritizing activities to meet regulatory needs for acute systemic lethality. ALTEX 38(2):327–335. 10.14573/altex.2012121.33511999
Tan YM, Barton HA, Boobis A, Brunner R, Clewell H, Cope R, Dawson J, Domoradzki J, Egeghy P, Gulati P, Ingle B, Kleinstreuer N, Lowe K, Lowit A, Mendez E, Miller D, Minucci J, Nguyen J, Paini A, Perron M, Phillips K, Qian H, Ramanarayanan T, Sewell F, Villanueva P, Wambaugh J, Embry M. 2021. Opportunities and challenges related to saturation of toxicokinetic processes: implications for risk assessment. Reg Toxicol Pharmacol 127:105070. 10.1016/j.yrtph.2021.105070.
Tandon A, Howard B, Ramaiahgari S, Maharana A, Ferguson S, Shah R, Merrick BA. 2021. Deep learning image analysis of high-throughput toxicology assay images. SLAS Discov 27(1):29–38. 10.1016/j.slasd.2021.10.014.35058173
Wei Z, Liu X, Ooka M, Zhang L, Song MJ, Huang R, Kleinstreuer NC, Simeonov A, Xia M, Ferrer M. 2020. Two-dimensional cellular and three-dimensional bio-printed skin models to screen topical-use compounds for irritation potential. Front Bioeng Biotechnol 8:109. 10.1021/acs.chemrestox.9b00228.32154236

### Abstracts

A searchable list of NICEATM and ICCVAM abstracts is available on the NTP website (https://ntp.niehs.nih.gov/go/804412).

Abedini J, Bell S, Chang X, Choksi N, Cook B, Daniel AB, Hines D, Karmaus AL, Mansouri K, Allen D, Kleinstreuer N. 2021. NICEATM computational tools and data resources [Abstract]. Presented at the 19th International Workshop on (Quantitative) Structure–Activity Relationships in Environmental Health Sciences; 7-10 June 2021.
Abedini JA, Bell S, Chang X, Cook BT, Karmaus AL, Mansouri K, Allen DG, Kleinstreuer NC. 2021. NICEATM computational tools and resources supporting alternative test method development and evaluation [Abstract 2542]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Abedini J, Bell S, Mansouri K, McAfee E, Phillips J, Chang X, Karmaus AL, Cook B, Allen D, Casey W, Kleinstreuer N. 2020. NICEATM computational tools and resources supporting alternative test method development and evaluation [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Abedini J, Cook B, McAfee E, Phillips J, Bell S, Rooney J, Allen D, Casey W, Kleinstreuer N. 2021. Utilizing ICE tools to expand chemical knowledge: Chemical Quest [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Adams VH, Reinke EN, Holden LA, LaScala JJ. 2020. In silico and in vitro analysis of 4-4’-methylenedianiline replacements [Abstract 3393]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Allen DG. 2020. Regulatory landscape and key considerations for establishing inhalation reference data [Continuing Education course presentation]. Presented as part of the 2020 Annual Meeting of the Society of Toxicology.
Allen DG. 2021. Retrospective analysis of dermal triple pack data [Abstract P225]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Allen DG, Rooney JP, Choksi N, Ceger P, Daniel A, Karmaus A, Strickland J, To K, Truax J, Casey W, Kleinstreuer N. 2021. Establishing confidence in NAMs: considering variability in reference test methods [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Allen DG, Rooney JP, Kleinstreuer NC, Lowit A, Perron M. 2021. Retrospective analysis of dermal absorption triple pack data [Abstract 2757]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Bell S. 2020. Integrated Chemical Environment [Continuing Education course presentation]. Presented as part of the 2020 Annual Meeting of the Society of Toxicology.
Bell S. 2021. Improving alternative method adoption through tools and resources to support community knowledge [Abstract 1008]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Bell S, Abedini J, Ceger P, Karmaus A, Daniel A, Choksi N, Rooney J, Allen D, Kleinstreuer N. 2020. Providing insight into chemical activity through data curation and assay annotation [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Bell S, Ceger P, Fostel J, Holmgren S, Masci AM, Allen D, Casey W, Kleinstreuer N. 2021. Accelerating adoption of NAMs with FAIR principles [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Bell S, Mansouri K, Phillips J, Chang X, Abedini J, Karmaus AL, Lea I, Rai R, Allen DG, Casey W, Kleinstreuer NC. 2020. NICEATM computational tools and resources supporting alternative test method development and evaluation [Abstract 2976]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Bishop P, Mansouri K, Allen D, Casey W, Kleinstreuer N. 2021. Acute oral toxicity predictions for environmental risk assessment [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Borba J, Braga R, Alves V, Muratov E, Kleinstreuer N, Tropsha A, Andrade C. 2020. Pred-Skin: a web portal for accurate prediction of human skin sensitizers [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Britton K, Korest D, Judson R, Jarema K, Coutros K, Wetmore B, Hill B, Hunter D, Olin J, Padilla S. 2020. Developmental toxicity assessment of a library of per- and polyfluoroalkyl substances in zebrafish (Danio rerio) embryos/larvae [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Casey W. 2020. Modernizing the NTP carcinogenicity testing program [Abstract]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Casey W. 2021. Incorporating NAMs into the DNTP carcinogenicity testing program [Abstract 1196]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Casey W. 2021. Modernizing the NTP’s carcinogenicity testing program [Abstract 11]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Casey W. 2021. Organ-on-a-chip validation efforts: challenges and lessons learned [Continuing Education course presentation]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Ceger P. 2021. Retrospective evaluation of the acute fish toxicity test for pesticide registration [Abstract P268]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Ceger P, Allen DG, Choksi N, Daniel A, Eckel W, Hamm J, Johnson T, Kleinstreuer NC, Lowit M, Sprankle C, Truax J, Odenkirchen E. 2021. Retrospective evaluation of the acute fish toxicity test for pesticide registration [Abstract 2324]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Ceger P, Garcia-Reyero N, Allen D, Arnold E, Bloom R, Brennan JC, Clarke C, Eisenreich K, Fay K, Hamm J, Henry PFP, Horak K, Hunter W, Judkins D, Klein P, Kleinstreuer N, Koehrn K, LaLone CA, Laurenson JP, Leet JK, Lowit A, Lynn SG, Norberg-King T, Perkins EJ, Petersen EJ, Rattner BA, Sprankle CS, Steeger T, Warren JE, Odenkirchen E. 2021. Determination of ecotoxicity testing needs among selected U.S. federal agencies [Abstract]. Presented at SETAC North America 2021; 14-18 November 2021.
Chang X. 2021. Toxicokinetic models for QIVIVE and consideration of uncertainty [Abstract]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Chang X. 2021. In vitro to in vivo extrapolation for developmental toxicity potency of valproic acid analogues [Abstract 442]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Chang X, Lumen A, Palmer J, Lee U, Ceger P, Donley B, Bell S, Allen D, Casey W, Kleinstreuer NC. 2020. In vitro to in vivo extrapolation for developmental toxicity potency of valproate analogues [Abstract P15]. Presented at the 60th Annual Meeting of the Society for Birth Defects Research and Prevention; 25 June-2 July 2020.
Chang X, Lumen A, Palmer J, Lee UJ, Ceger P, Donley E, Bell S, Allen D, Kleinstreuer N. 2020. In vitro to in vivo extrapolation for developmental toxicity potency of valproic acid analogues [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Chang X, Lumen A, Palmer J, Lee UJ, Ceger P, Donley E, Bell S, Allen D, Casey W, Kleinstreuer N. 2020. In vitro to in vivo extrapolation for developmental toxicity potency of valproic acid analogues [Abstract 1612]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Chang X, Palmer J, Donley E, Allen D, Casey W, Kleinstreuer N. 2021. In vitro to in vivo extrapolation for developmental toxicity potency of selected Tox21 chemicals [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Choksi N. 2021. Developing a defined approach for eye irritation testing [Abstract P505]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Choksi N, Clippinger AJ, Gehen S, Corvaro M, Kolle SN, Bentley K, Hofstra A, Inforzato M, Ryan N, Webb E, Casey W, Allen DG. 2020. Developing a defined approach for eye irritation testing [Abstract 2198]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Choksi N, Clippinger AJ, Gehen S, Corvaro M, Kolle SN, Bentley K, Hofstra A, Inforzato M, Ryan N, Webb E, Casey W, Allen D. 2020. Testing of agrochemical formulations using in vitro and ex vivo eye irritation test methods [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Cook B, Abedini J, Bell S, McAfee E, Phillips J, Allen D, Kleinstreuer N. 2021. Chemical exploration: providing biological context for NAMs [Abstract]. Presented at the 19th International Workshop on (Quantitative) Structure–Activity Relationships in Environmental Health Sciences; 7-10 June 2021.
Cook B, Abedini J, Bell S, McAfee E, Phillips J, Allen D, Kleinstreuer N. 2020. Chemical exploration: identifying bioactivity with the use of structural features [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Cook B, Abedini JA, Bell S, McAfee E, Phillips J, Rooney JP, Allen DG, Kleinstreuer NC. 2021. Providing context for chemical effects through bioactivity and consumer use [Abstract 2541]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Daniel AB, Abedini JA, Bell S, Chang X, Cook B, Karmaus AL, Hines DE, McAfee E, Phillips J, Rooney JP, Allen DG, Kleinstreuer NC. 2021. Updates to the Integrated Chemical Environment: expanding tools and data to support toxicity assessments [Abstract 2958]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Farcas MT, Stefaniak AB, McKinney W, Knepp AK, Bowers L, Mandler WK, Kashon M, Battelli L, Stueckle TA, Orandle M, Winn A, Friend SA, Jackson SR, Qi C, Hammond DR, Mercer R, LeBeouf R, Burns D, Ranpara A, Thomas TA, Matheson J, Castranova V, Qian Y. 2020. Toxicological evaluation of acrylonitrile butdiene styrene (ABS) 3D printer emissions [Abstract 1679]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Fitzpatrick S. 2020. In vitro microphysiological systems: advancing regulatory science through innovation [Abstract]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Fitzpatrick S. 2021. Developing performance based qualification criteria for organs on a chip [Abstract 946]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Fitzpatrick S. 2021. Implementing new testing approaches at the US Food and Drug Administration [Continuing Education course presentation]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Foster C. 2021. Standardizing developmental toxicology study extractions using automated application of ontologies [Abstract P576]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Foster C, Wignall J, Kovach S, Trgovcich J, Varghese A, Rochester J, Stout M, Kleinstreuer NC. 2020. Automated applications of ontologies to standardize developmental toxicology study extraction [Abstract 25]. Presented at the 60th Annual Meeting of the Society for Birth Defects Research and Prevention; 25 June-2 July 2020.
Gombar V, Sedykh A, Ross A, Casey W, Shah R. 2021. OrbiTox: a translational discovery platform for concerted view and analysis of big data [Abstract 2802]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Gombar V, Sedykh A, Ross A, Witt K, Shah R, Casey W. 2021. OrbiTox: a translational discovery platform for concerted view and analysis of multi-domain data [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Gordon JD, Uhl R, Toman B, Elliot J, Petersen E. 2020. Using a measurement science approach to increase confidence in the EASA skin sensitization assay [Abstract 1417]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Gordon JD, Uhl R, Toman B, Elliot J, Petersen E. 2020. EASA skin sensitization assay development: using a measurement science approach to increase confidence [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Guo X, Seo J, Wu Q, Manjanatha MG, Mei N. 2021. Performance of metabolically competent HepaRG cells for genotoxicity testing: a comparison between three human hepatic cells using the high-throughput micronucleus and comet assays [Abstract 2806]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Hamm J. 2021. Performance of the GHS mixtures equations for predicting acute oral toxicity [Abstract P572]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Hamm J, Allen DG, Ceger P, Flint T, Kleinstreuer NC, O’Dell L, Tao JJ, Lowit A. 2021. Predicting oral acute toxicity using the GHS additivity equation [Abstract 2345]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Henry TR, Salazar KD, Hayes MP, Kennedy W, Keene AM, Jarabek AM, Price OT, Moors S, Jovanovich L, Rose JL, Tveit A, Tremblay RT, Becker RA, Osman-Sypher S, McMullen PD, Slattery SD, Irwin W, Odin M, Melia J, Sharma M, Clippinger AJ, Stucki A, Stedeford T. 2021. Surfactants category: an integrated approach to testing and assessment (IATA) including new approach methods (NAMs) for assessing inhalation risks under the Toxic Substances Control Act (TSCA) [Abstract 2583]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Hill BN, Hunter DL, Padilla S. 2020. Zebrafish larval locomotor activity is depressed by lack of swim bladder inflation or dimethyl sulfoxide [Abstract 1461]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Hilton GM, Akerman G, Baldassari J, Battalora M, Buesen R, Clippinger AJ, Geter D, Lowit A, Melching-Kollmuss S, Kormos T, Papineni S, Peffer RC, Williamson Riffle B, Ryan N, Visconti N, Wolf DC. 2020. Rethinking carcinogenicity assessment for agrochemicals [Abstract 2200]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Hines D, Bell S, Chang X, Mansouri K, Allen D, Casey W, Kleinstreuer N. 2021. Computational support of pharmacokinetic models and in vitro to in vivo extrapolation [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Jarabek AM, Stedeford T, Ladics GS, Price OT, Tveit A, Hayes MP, Tremblay RT, Snyder SA, Salazar KD, Osman-Sypher S, Irwin W, Odin M, Melia J, Carlson-Lynch H, Sharma M, Clippinger AJ, Stucki AO, Henry TR. 2021. Poorly soluble, low toxicity (PSLT) polymer category: an integrated approach to testing and assessment (IATA) including new approach methods (NAMs) under the Toxic Substances Control Act (TSCA) [Abstract 2593]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Kaldhone P, Yan J, Chen T, Manjanatha M. 2020. Glyphosate safety assessment through Ames test [Abstract 1668]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Kang JC, Valerio L. 2020. Investigating DNA adduct formation by flavor chemicals and tobacco byproducts in electronic nicotine delivery system (ENDS) using in silico approaches [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Karmaus AL 2021. Comparing and interpreting Tox21 data analysis approaches [Abstract 1000]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Karmaus AL. 2021. Interpreting the Tox21 data analysis methods toward a consensus [Continuing Education course presentation]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Karmaus AL. 2021. Rat acute systemic toxicity testing: evaluating reproducibility and inherent variability [Abstract P232]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Karmaus A, Rooney J, Ceger P, Abedini J, Phillips J, Bell S, Allen D, Kleinstreuer N. 2021. Annotating and visualizing in vitro data to gain context [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Kleinstreuer NC. 2020. Computational crowdsourcing: leveraging global expertise to predict toxicity [Abstract]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Kleinstreuer NC. 2020. What do computational toxicology tools offer? [Continuing Education course presentation]. Presented as part of the 2020 Annual Meeting of the Society of Toxicology.
Kleinstreuer NC. 2020. Establishing international test guidelines for skin sensitization: predictive capacity and applicability domain of nonanimal-defined approaches [Abstract]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Kleinstreuer NC. 2021. Automated approaches to anchoring alternatives [Abstract]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Kleinstreuer NC. 2021. Applying in vitro to in vivo extrapolation to NAM-derived PODs [Abstract 49]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Kleinstreuer NC. 2021. Building an AOP-driven defined approach guideline [Abstract 47]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Kleinstreuer NC. 2021. High-throughput screening to predict HERG inhibition [Abstract P577]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Kleinstreuer NC. 2021. International regulatory progress on nonanimal approaches for skin sensitization [Abstract 1283]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Kleinstreuer NC. 2021. The intersection of scientific advances and regulatory needs [Abstract]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Kleinstreuer NC. 2021. Introduction to skin sensitisation NAMs and defined approaches [Abstract]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Kleinstreuer NC. 2021. A North American regulatory perspective on skin sensitization risk assessment [Abstract 48]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Kleinstreuer NC. 2021. “Proof in animals”: has journal editorial policy fallen behind advances in human-based approaches [Abstract]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Kleinstreuer NC. 2021. Systematic evidence mapping of research on environmental exposures and cardiovascular disease [Abstract P578]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Krishna S, Berridge BR, Kleinstreuer N. 2020. Predicting putative cardiotoxic chemicals using Tox21 qHTS data [Abstract 3131]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Krishna S, Beverley B, Walker V, Kleinstreuer N, Rooney A. 2021. Systematic evidence mapping of research on environmental exposures and cardiovascular disease [Abstract 2791]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Krishna S, Beverley B, Walker V, Kleinstreuer N, Rooney A. 2021. Systematic evidence mapping of research on environmental exposures and cardiovascular disease [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Krishna S, Borrel A, Huang R, Zhao J, Xia M, Kleinstreuer N. 2021. High-throughput screening to predict hERG inhibition [Abstract 2561]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Krishna S, Borrel A, Huang R, Zhao J, Xia M, Kleinstreuer N. 2021. High-throughput screening to predict hERG inhibition [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Lavrich K, Ramiahgari S, Urbano N, Merrick BA, Ferguson S. 2020. Modeling inter-individual susceptibility in toxicological screening using 3D spheroid primary human hepatocyte cultures [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Li X, He X, Chen S, Guo X, Bryant MS, Guo L, Manjanatha MG, Mei N. 2021. The genotoxicity of pyrrolizidine alkaloids is mediated by CYP3A in metabolically competent TK6 cell lines [Abstract 2804]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Lowit A. 2021. Recent progress toward reducing animal use and adopting new approach methods [Abstract 1134]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Lowit M, Ceger P, Allen D, Arnold E, Choksi N, Daniel A, Hamm J, Judkins D, Kleinstreuer N, Montague B, Sprankle C, Truax J, Odenkirchen E. 2020. Exploring ways to reduce animal testing in support of the registration of pesticides by the U.S. Environmental Protection Agency [Abstract]. Presented at SETAC North America 2020; 15-19 November 2020.
Lowit M, Ceger P, Allen D, Choksi N, Daniel A, Eckel, W., Hamm J, Johnson, T., Kleinstreuer N, Sprankle C, Truax J, Odenkirchen E. 2021. Applying the 3Rs to Reduce Animal Testing in Support of the Registration of Pesticides by the U.S. Environmental Protection Agency [Abstract]. Presented at SETAC Europe 2021; 3-6 May 2021.
Lowit M. 2021 Exploring Ways to Reduce Animal Testing in a Regulatory Context. [Abstract]. Presented at SETAC Europe 2021; 3-6 May 2021.
Mansouri K. 2021. OPERA, an open-source and open-data suite of QSAR models [Abstract P508]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Mansouri K, Chang X, Allen D, Casey W, Kleinstreuer N. 2021. QSAR models supporting toxicokinetic modeling and in vitro to in vivo extrapolation [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Mansouri K, Chang X, Judson R, Williams A, Allen DG, Kleinstreuer NC. 2021. OPERA models for ADME properties and toxicity endpoints [Abstract 2543]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Mansouri K, Karmaus AL, Fitzpatrick J, Patlewicz G, Pradeep P, Allen DG, Casey W, Kleinstreuer NC. 2020. Collaborative modeling project for predicting acute oral toxicity [Abstract 2060]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Mansouri K, Karmaus A, Fitzpatrick J, Patlewicz G, Pradeep P, Allen D, Casey W, Kleinstreuer N. 2020. Collaborative modeling project for predicting acute oral toxicity (CATMoS) [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Mansouri K, Karmaus A, Fitzpatrick J, Patlewicz G, Pradeep P, Allen D, Casey W, Kleinstreuer N. 2020. International computational modeling collaborations for predictive toxicology [Abstract]. Presented at SETAC North America 2020; 15-19 November 2020.
Mansouri K, Grulke C, Judson R, Richard A, Williams A, Kleinstreuer N. 2021. Open-source QSAR-ready chemical structure standardization workflow [Abstract]. Presented at the 19th International Workshop on (Quantitative) Structure–Activity Relationships in Environmental Health Sciences; 7-10 June 2021.
Mansouri K, Karmaus A, Fitzpatrick J, Patlewicz G, Pradeep P, Allen D, Casey W, Kleinstreuer N. 2021. Collaborative modeling project for predicting acute oral toxicity (CATMoS) [Abstract]. Presented at the 19th International Workshop on (Quantitative) Structure–Activity Relationships in Environmental Health Sciences; 7-10 June 2021.
Martin MM, Baker NC, Boyes WK, Carstens KE, Culbreth ME, Gilbert ME, Harrill JA, Nyffeler J, Padilla S, Paul-Friedman K, Shafer TJ. 2021. An expert-driven literature review of “negative” reference chemicals for developmental neurotoxicity (DNT) assay evaluation [Abstract 2554]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Medlock Kakaley E, Cardon M, Evans N, Bradley P, Iwanowicz L, Gray E, Hartig P, Wilson V. 2020. In vitro bioassay and screening model for pre- and post-distribution for chicago-area treated waters [Abstract 1889]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Mumtaz MM, Pohl HR. 2020. Joint toxicity assessment of perfluoroalkyl substances (PFAS) mixtures [Abstract 2820]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Ooka M, Zhao J, Huang R, Witt K, Ferguson S, Smith-Roe S, Simeonov A, Xia M. 2021. Profiling Tox21 compounds that activate p53 signaling after metabolic activation [Abstract 2761]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Petersen E, Sharma M, Clippinger A, Gordon J, Katz A, Laux P, Leibrock L, Luch A, Matheson J, Stucki A, Tentschert J, Bierkandt F. 2021. Use of cause-and-effect analysis to optimize the reliability of in vitro inhalation toxicity measurements using an air–liquid interface [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Rahman A, Svoboda D, Bushel PR, Berridge BR, Auerbach SS. 2020. Weighted gene coregulation network analysis (wgcna) to decipher temporal dynamics in cardiotoxicity [Abstract 3102]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Rooney JP. 2021. Variability in the rabbit skin irritation assay [Abstract P509]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Rooney J, Abedini J, Bell S, Chang X, Cook B, Ceger P, Hines D, Karmaus A, McAfee E, Phillips J, Allen D, Casey W, Kleinstreuer N. 2021. Building confidence in alternative methods through ICE [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Rooney JP, Choksi N, Ceger P, Daniel A, Truax J, Rai R, Kleinstreuer N, Allen D. 2020. Variability in the rabbit skin irritation assay [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Rooney JP, Choksi N, Ceger P, Daniel AB, Truax J, Allen DG, Kleinstreuer NC. 2021. Variability in the rabbit skin irritation assay [Abstract 2760]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Rooney JP, Choksi N, Rai R, Allen DG, Kleinstreuer NC, Casey W. 2020. Variability in the rabbit skin irritation assay [Abstract 1415]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Rooney J, Lizarraga L, Yamada T, Allen D, Babich M, Daniel A, Fitzpatrick S, Garcia-Reyero N, Gordon J, Hakkinen P, Karmaus A, Kleinstreuer N, Matheson J, Mumtaz M, Rua D, Ruiz P, Scarano L, Volarath P, Patlewicz G. 2020. ICCVAM Read-Across Workgroup: towards guiding principles for read-across applications [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Ruiz P, Boone S, Mumtaz MM. 2020. Advantage of read-across and pharmacokinetics modeling for the exposure assessment of persistent organic pollutants [Abstract 2949]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Sedykh A. 2021. Mixture-based QSAR models of ocular toxicity for regulatory hazard categories [Abstract P230]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Sprankle C. 2021. Effective user support documentation for a toxicological data resource: ICE as a case study [Abstract P513]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Strickland J. 2021. Application of defined approaches for skin sensitization to agrochemical products [Abstract P511]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Strickland J. 2021. International regulatory needs for acute toxicity data [Abstract P586]. Presented at the 11^th^ World Congress on Alternatives and Animal Use in the Life Sciences; 23 August-2 September 2021.
Strickland J, Allen DG, Api A, Gordon J, Kleinstreuer NC, Ko HS, Matheson J, Thierse HJ, Truax J, Herzler M. 2020. Classification of human reference data for skin sensitization [Abstract 1872]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Strickland J, Allen D, Api AM, Gordon J, Kleinstreuer N, Ko HS, Matheson J, Thierse HJ, Truax J, Herzler M. 2020. Human reference database for skin sensitization [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.
Strickland J, Allen D, Api AM, Gordon J, Kleinstreuer N, Ko HS, Matheson J, Thierse HJ, Truax J, Herzler M. 2021. Compilation and characterization of a human skin sensitization data set [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Strickland J, Daniel AB, Allen DG, Kleinstreuer NC, Haugabrooks E. 2021. International regulatory needs for acute toxicity data [Abstract 2341]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
Strickland J, Truax J, Corvaro M, Settivari R, Henriquez J, McFadden J, Gulledge T, Johnson V, Gehen S, Germolec D, Allen D, Kleinstreuer N. 2021. Skin sensitization testing of mixtures without animals [Abstract]. Presented at the Tenth Annual Meeting of the American Society for Cellular and Computational Toxicology; 12-14 October 2021.
Tan C, Lowit A, Embry M. 2020. Applications of physiologically based pharmacokinetic (PBPK) modeling in regulatory risk assessment for pesticides [Abstract 1539]. Accepted for presentation at the 2020 Annual Meeting of the Society of Toxicology.
Tandon A, Maharana A, Howard B, Ramaiahgari S, Dunlap P, Rice J, Merrick A, DeVito M, Ferguson S, Shah R. 2021. Toward automation of high-throughput toxicology assay image analysis using deep learning [Abstract 2977]. Presented at the Annual Meeting of the Society of Toxicology; 12-26 March 2021.
You D, Behl M, Choi T, Balik-Meisner M, Mav D, Phadke D, Shah R, Harrill A. 2020. Molecular assessment of interindividual variability in susceptibility to developmental neurotoxicity of methyl mercury using diversity outbred neural progenitor cells [Abstract]. Presented at the Ninth Annual Meeting of the American Society for Cellular and Computational Toxicology; 20-22 October 2020.

### Articles in the NIEHS Environmental Factor newsletter

Tags: ICCVAM, NIEHS, VA ORD, acute toxicity, antibodies, COVID-19, MPS, skin sensitization

Lenox K. January 2020. Chronic inflammation needs focused research to reduce disease. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2020/1/papers/inflammation/index.htm.
Sprankle C. January 2020. Moving away from animal-based antibodies. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2020/1/science-highlights/cell-based-antibodies/index.htm.
Sprankle C. July 2020. Reductions in animal testing celebrated at national meeting. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2020/7/science-highlights/nonanimal-testing/index.htm.
Sprankle C. September 2020. Animal testing alternatives advanced by 16 government agencies. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2020/9/science-highlights/animal-testing/index.htm.
Sprankle C. October 2020. Nonanimal safety testing requires data quality, measures of success. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2020/10/science-highlights/safety-testing/index.htm.
Sprankle C. December 2020. Department of Veterans Affairs joins effort to reduce animal testing. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2020/12/science-highlights/va/index.htm.
Sprankle C. March 2021. Organs-on-a-chip for COVID-19 research group led by NTP center. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2021/3/science-highlights/organ-chip/index.htm.
Sprankle C. May 2021. New predictive model may speed toxicity screens, reduce animal use. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2021/5/papers/predictive-toxicity/index.htm.
Sprankle C. July 2021. Animal replacement accomplishments draw broad interest. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2021/7/science-highlights/nonanimal-methods/index.htm.
Sprankle C. August 2021. New chemical testing approach will help to replace animal use. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2021/8/science-highlights/nonanimal-testing/index.htm.
Sprankle C. November 2021. Agencies advised on reducing animal testing, embracing alternatives. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2021/11/science-highlights/nonanimal-methods/index.htm.
Weaver J. March 2021. Computational toxicology featured in special journal issue. Environmental Factor [Internet]. [cited 30 Mar 2022] Available from: https://factor.niehs.nih.gov/2021/3/papers/comp-tox/index.htm.

## Glossary of Key Terms

3Rs: the principles of replacement, reduction, or refinement of animal use for scientific research or product safety testing.
Accuracy: in the context of a test method validation study, the closeness of agreement between a test method result and an accepted reference value, or the test method’s proportion of correct outcomes.
Acute systemic toxicity: the immediate or near-immediate effect of a toxic substance after it is absorbed and distributed throughout the body. Different acute systemic toxicities are distinguished by the route of exposure: by ingestion (oral), through the skin (dermal), or by inhalation.
Adverse outcome pathway (AOP): a conceptual framework constructed from existing knowledge that relates exposure of a type of toxic substance to subsequent steps that result in illness or injury.
Agonist: a substance that increases activity of the target receptor.
Algorithm: a set of steps that are followed to complete a computational process.
Allergic contact dermatitis: an allergic reaction that results from repeated direct skin contact with a skin sensitizer. Clinical signs of allergic contact dermatitis include redness, swelling, blistering, and itching.
Alternative methods: testing methods or approaches that replace, reduce, or refine animal use; the term new approach methodologies is also used and is becoming more prevalent.
Androgen: a class of hormones, produced largely by the testes, that serve as the primary male hormones.
Androgen receptor: a protein molecule to which an androgen or androgen-like substance can attach. This interaction produces a chemical signal or triggers a cellular response.
Aneugen: a chemical agent that causes dividing cells to pass on an abnormal number of chromosomes to the descendant cells.
Antagonist: a substance that decreases activity of the target receptor.
Applicability domain: a range of chemicals and properties for which a test method has been proven useful.
Bioactivity: the manner in which a chemical affects or interacts with living tissue.
Biomarker: an objective measure that captures what is happening in a cell or an organism at a given moment.
Bioprinting: a process that combines 3D printing with biomaterials to replicate parts that imitate natural tissues, bones, and blood vessels in the body.
Cardiotoxicity: toxicity to the heart.
Chorion: in fish, the outermost membrane of an egg.
Clastogen: a chemical that can cause breaks in chromosomes, leading to sections of the chromosome being deleted, added, or rearranged.
Concentration–response curve: a curve on a graph that shows the relationship between the concentration of a chemical being tested in an assay and its measured effect on the assay endpoint.
Cytotoxic: the ability of a substance to kill or harm cells.
Defined approach: a testing strategy that consists of input data generated from identified methods and a data interpretation procedure, such as a machine learning model, flowchart, or decision tree, through which the data are evaluated.
Developmental toxicity: effects observed in offspring that occur as a result of chemical exposures of the pregnant mother.
Dosimetry: measurement or calculation of a dose of substance delivered to a target tissue.
Ecotoxicity testing: refers both to the assessment of chemical effects on invertebrates, fish, birds, plants, and other wild organisms and testing of soil, sediment, or effluents for the presence of toxic compounds.
Endocrine disruptor: a natural or man-made substance that may interfere with the endocrine system and produce adverse health effects.
Environmental fate properties: properties of a chemical, such as biodegradability and soil adsorption, that affect how it will behave if released into the environment.
Epithelial cells: any of the cells forming the cellular sheets that cover surfaces, both inside and outside the body.
Equivalent administered dose: the output of in vitro to in vivo extrapolation; the predicted in vivo dose that would result in a plasma concentration of a chemical equal to the concentration of that chemical that induces an effect in an in vitro assay.
Estrogen: a class of hormones, produced largely by the ovaries, that serve as the primary female hormones.
Estrogen receptor: a protein molecule to which an estrogen or estrogen-like substance can attach. This interaction produces a chemical signal or triggers a cellular response.
Ex vivo: refers to an assay using tissue that has been removed from a multicellular organism and conducted while the tissue is still viable.
Formulation: a mixture of chemicals prepared according to a specific procedure to ensure a desired effect when used, improve handling properties, or achieve other desired product goals.
G protein-coupled receptor: receptors located in the cell membrane involved in cell signaling. G protein-coupled receptors are important drug target and involved in many diseases.
Genotoxic: capable of damaging DNA.
Harmonization: the act of making systems or laws similar among different companies, countries, etc., so the organizations using those systems or laws can operate more easily within the different venues.
Hazard classification: assignment of a substance to a category according to results of toxicity testing, often for labeling purposes.
Hepatic: referring to the liver.
Hepatocyte: the main functional cell of the liver.
Hepatotoxicity: toxicity to the liver.
High-content screening: an approach that uses fluorescent tagging and automated imaging to assess changes in the structure and composition of individual cells in a high-throughput manner.
High-throughput screening (HTS): a testing approach that uses robotics, liquid-handling devices, detectors, and associated software to quickly conduct a large number of chemical or biochemical tests.
Homeostasis: the maintenance of physical and chemical conditions by living systems to allow optimal functioning of the organism.
In chemico: refers to assays that are carried out in an artificial system, such as a test tube or assay plate, using only chemical components rather than cells.
In silico: refers to analyses that are carried out on a computer or via computer simulation.
In vitro: refers to assays that are carried out in an artificial system, such as a test tube or assay plate, using small single-cell or multicellular organisms, cultured cells, or cellular components.
In vitro to in vivo extrapolation (IVIVE): an analysis conducted to relate the test chemical concentration causing a response in an in vitro system to an external dose or exposure that results in human or animal (in vivo) illness or injury at the target tissue.
In vivo: refers to assays carried out using multicellular organisms, typically rodents or other mammals.
Induced pluripotent stem cells (iPSCs): stem cells derived from mature non-sex cells that have the potential to differentiate into various types of cells.
Integrated approach to testing and assessment (IATA): an approach that considers all available relevant information about a substance in a weight-of-evidence assessment to inform a regulatory decision regarding hazard or risk, or to indicate that specific additional tests are needed.
Keratinocyte: the major cell type of the skin.
LC50: in traditional animal tests for acute inhalation or aquatic toxicity, the concentration that causes death in 50 percent of the animals tested; a value used to categorize toxic substances and determine the hazard phrases used on product labels.
LD50: in traditional animal tests for acute systemic oral or dermal toxicity, the dose that causes death in 50 percent of the animals tested; a value used to categorize toxic substances and determine the hazard phrases used on product labels.
Leukocyte: any of the colorless blood cells of the immune system.
Machine learning: the study and construction of computer algorithms that, once trained on a set of data, can make predictions or decisions about a different set of data.
Metabolism: the sum of the processes by which a particular substance is handled in a living organism, such as assimilation and incorporation or detoxification and excretion.
Microphysiological systems (MPS): in vitro models of organs composed of cells and structural materials that are designed to reproduce the function of living organs; also referred to as organs-on-a-chip or tissue chips.
Microtiter plate: a flat plate with multiple wells used as small test tubes.
Nanomaterial: a substance made up of particles that measure no more than 100 nanometers in at least one dimension.
Neurotoxicity: toxicity to the brain or other parts of the nervous system.
New approach methodologies (NAMs): testing methods or approaches that replace, reduce, or refine animal use; the term alternative methods has also been widely used.
Nonclinical testing: evaluation of candidate drugs conducted in animals or in vitro assays, typically before testing in humans to assess toxicity and determine safe doses; the term “preclinical testing” is also used.
Ontologies: standardized nomenclature systems.
Organophosphorus compounds: organic compounds that contains phosphorus; many are used as pesticides.
Per- and polyfluoroalkyl substances (PFAS): a class of manufactured chemicals that are widely used to make various types of common products. While their potential health impacts are mostly uncharacterized, they are of concern because they resist degradation, accumulate in an organism’s body over its lifetime, and are widespread in the environment.
Pharmacokinetics: an evaluation of the rate at which a chemical is absorbed, distributed, metabolized, and excreted once it enters the body, as a means to determine the relationship between exposure and toxicity (see also toxicokinetics).
Pharmacokinetic (PK) model: a mathematical model created to describe the process of absorption, distribution, metabolism, and excretion of a chemical through the body. One-compartment models treat all organs as a single unit, whereas physiologically based (PBPK) models are usually multicompartment models with separate compartments corresponding to individual or combined organs that are interconnected by blood flows.
Phenotype: observable characteristics of an organism resulting from the interaction of its genetic makeup with the environment.
Physicochemical properties: referring to the physical or chemical properties of a substance.
Point of departure (POD): the lowest dose or concentration at which a treatment-related response is observed.
Polymorphisms: in the context of genetics, differences in an organism’s DNA sequence. While most polymorphisms have no effect on health or development, some of these genetic differences are related to functional effects such as variation in chemical metabolism.
Quantitative structure–activity relationship (QSAR) models: classification models that predict the activities of chemicals with unknown properties by relating them to properties of known chemicals.
Read-across: a computational technique that uses toxicity data from one or more known (source) chemicals to predict toxicity for another (target) chemical, usually but not always on the basis of structural similarity.
Reference chemical: a chemical that causes a specific well-characterized biological effect, and therefore, can be used to assess the performance of a test method designed to measure that effect. Reference chemicals should represent the classes of chemicals for which a test method is proposed to be used and cover the range of expected responses.
Reference data: data from an accepted test method that can be used to assess the performance of a new test method designed to measure an analogous effect.
Refinement alternative: a test method that modifies procedures to enhance animal well-being and that lessens or avoids pain and distress in animals.
Relevance: the extent to which a test method accurately measures a biological effect of interest in a species of interest.
Reliability: the extent to which a test method provides reproducible results over time and in different laboratories.
Replacement alternative: a test method that replaces animals with a non-animal system or one animal species with a phylogenetically lower one.
Reproductive toxicity: chemical effects on the reproductive system that interfere with an organism’s sexual function or fertility.
Risk assessment: the process of characterizing the potential risk posed by a chemical, taking into consideration the hazards posed by the chemical, the dose of the chemical needed to cause health problems, and the probability of exposure at that dose.
Sensitivity: in the context of test method validation, the proportion of all positive substances that are correctly classified as positive by the test method under evaluation.
Skin irritation: minor injury or inflammation to the skin; irritation differs from an allergic reaction in that there is no coordinated response from the immune system.
Skin sensitization: a hypersensitivity reaction that occurs when a susceptible person comes in direct skin contact with an allergen, termed a skin sensitizer.
Skin sensitization potency: the relative amount of a substance that produces a skin sensitization reaction.
Specificity: in the context of test method validation, the proportion of all negative substances that are correctly classified as negative by the test method under evaluation.
Stem cells: undifferentiated cells of a multicellular organism that can indefinitely produce more cells of the same type and can also be induced to differentiate into other types of cells (see also induced pluripotent stem cells).
Subacute: animal experiment designed to study effects produced by the test substance when administered either in repeated doses or continually in food, drinking water, or air over a period of between 24 h and 28 days.
Subchronic: animal experiment designed to study effects produced by the test substance when administered either in repeated doses or continually in food, drinking water, or air over a period of up to about 90 days.
Sublethal: a dose or concentration of a substance that is not high enough to cause death.
Tox21: collaborative effort among four U.S. federal government agencies to develop more efficient approaches to predict how chemicals may affect human health.
Toxicant: a toxic or poisonous substance.
Toxicokinetics: an evaluation of the rate at which a chemical is absorbed, distributed, metabolized, and excreted once it enters the body, as a means to determine the relationship between exposure and toxicity (see also pharmacokinetics).
Transcriptomics: the analysis of overall gene expression in a cell or tissue to assess cell function or response to toxicity.
Uterotrophic assay: an assay conducted in female rodents that measures the estrogenic activity of a chemical by assessing the chemical’s effect on the weight of the uterus.
Validation: a process by which the reliability and relevance of a test method are established for its intended application.
Xenobiotic: a chemical found within an organism that is not naturally produced or expected to be present within the organism.

## Acronyms and Abbreviations

3Rs: principles of replacement, reduction, or refinement of animal use for scientific research or product safety testing
ADME: absorption, distribution, metabolism, and excretion
AOP: adverse outcome pathway
API: application programming interface
ATSDR: Agency for Toxic Substances and Disease Registry
AWIC: Animal Welfare Information Center (U.S. Department of Agriculture)
BraCVAM: Brazilian Center for the Validation of Alternative Methods
CaCVAM: Canadian Centre for the Validation of Alternative Methods
CarciHEI: Carcinogenicity Health Effects Innovation Program (National Institute of Environmental Health Sciences)
CATMoS: Collaborative Acute Toxicity Modeling Suite
CDER: Center for Drug Evaluation and Research (U.S. Food and Drug Administration)
CPSC: U.S. Consumer Product Safety Commission
DNT HEI: Developmental Neurotoxicity Health Effects Innovation Program (National Institute of Environmental Health Sciences)
DNTP: Division of the National Toxicology Program (National Institute of Environmental Health Sciences)
DoD: U.S. Department of Defense
DOE: U.S. Department of Energy
DOI: U.S. Department of the Interior
DOT: U.S. Department of Transportation
dTP: developmental toxicity potential
ELISA: enzyme-linked immunosorbent assay
ENM: engineered nanomaterials
EPA: U.S. Environmental Protection Agency
EURL ECVAM: European Union Reference Laboratory for Alternatives to Animal Testing
FAIR: findability, accessibility, interoperability, and reusability (of data)
FDA: U.S. Food and Drug Administration
FXR: farnesoid X receptor
GHS: United Nations Globally Harmonized System of Classification and Labelling of Chemicals
HTS: high-throughput screening
httk: High-throughput Toxicokinetics (software package, U.S. Environmental Protection Agency)
IATA: integrated approach to testing and assessment
ICATM: International Cooperation on Alternative Test Methods
ICCVAM: Interagency Coordinating Committee on the Validation of Alternative Methods
ICE: Integrated Chemical Environment (National Toxicology Program)
ICH: International Council for Harmonisation of Technical Requirements for Pharmaceuticals for Human Use
iPSC: induced pluripotent stem cell
IVIVE: in vitro to in vivo extrapolation]
JaCVAM: Japanese Center for the Validation of Alternative Methods
KM: half-maximal concentration for metabolism
KoCVAM: Korean Center for the Validation of Alternative Methods
LC50: in traditional acute inhalation or aquatic toxicity tests, the concentration that produces lethality in 50% of the animals tested
LD50: in traditional acute dermal or oral systemic toxicity tests, the dose that produces lethality in 50% of the animals tested
LEL: lowest effect level
LOAEL: lowest observable adverse effect level
MAT: monocyte activation tests
MPS: microphysiological systems
MPSCoRe: MPS for COVID Research working group
NAM: new approach methodology
NASA: National Aeronautics and Space Administration
nAChRs: nicotinic acetylcholine receptors
NC3Rs: National Centre for the Replacement Refinement & Reduction of Animals in Research (United Kingdom)
NCATS: National Center for Advancing Translational Sciences (National Institutes of Health)
NCI: National Cancer Institute (National Institutes of Health)
NICEATM: National Toxicology Program Interagency Center for the Evaluation of Alternative Toxicological Methods
NIEHS: National Institute of Environmental Health Sciences (National Institutes of Health)
NIH: National Institutes of Health
NIOSH: National Institute for Occupational Safety and Health
NIST: National Institute of Standards and Technology
NLM: National Library of Medicine (National Institutes of Health)
NTP: National Toxicology Program
OECD: Organisation for Economic Co-operation and Development
OPERA: Open (Quantitative) Structure–activity/property Relationship App
OSHA: Occupational Safety and Health Administration
PAH: polycyclic aromatic hydrocarbon
PBPK: physiologically based pharmacokinetic
PFAS: per- and polyfluoroalkyl substances
PHMSA: Pipeline and Hazardous Materials Safety Administration (U.S. Department of Transportation)
PK: pharmacokinetic
POD: point of departure
QSAR: quantitative structure–activity relationship
RHDV2: rabbit hemorrhagic disease virus serotype 2
SACATM: Scientific Advisory Committee on Alternative Toxicological Methods
SARA: Skin Allergy Risk Assessment model (Unilever)
SEAZIT: Systematic Evaluation of the Application of Zebrafish in Toxicology (National Toxicology Program)
SOT: Society of Toxicology
ToxCast: Toxicity Forecaster (U.S. Environmental Protection Agency)
ToxRefDB: Toxicity Reference Database (U.S. Environmental Protection Agency)
TSCA: Toxic Substances Control Act (U.S. Environmental Protection Agency)
USDA: U.S. Department of Agriculture
USGS: U.S. Geological Survey (U.S. Department of the Interior)
Vmax: maximal capacity for metabolism