# Day 1 Summary

## Welcome

### Maureen Gwinn (U.S. EPA): Welcome

Dr. Maureen Gwinn opened the conference and welcomed participants. She indicated that the conference would highlight EPA’s continued commitment to the development and implementation of NAMs and showcase how EPA continues to serve as a leader in developing these methods and technologies to reduce the need for the use of animals in research while using the best science to support Agency decisions. Dr. Gwinn emphasized EPA’s comprehensive NAMs Work Plan, which was created to prioritize Agency efforts and resources toward activities aimed at reducing the use of vertebrate animal testing while continuing to protect human health and the environment. She also noted the ongoing efforts to maintain and update the list of EPA-recommended NAMs, per the Toxic Substances Control Act (TSCA), which includes an upcoming release of a draft proposal on the process for selecting which NAMs will be included in future versions of said list. Dr. Gwinn also discussed the importance of stakeholder engagement. She described EPA’s ongoing stakeholder engagement efforts which include regular updates to EPA’s NAMs website,^1^ a NAMs training program, soliciting input from stakeholders on the development and updates to NAM methods and confidence evaluation, and the allocation of research grants to advance NAMs. She concluded by stating that the presentations and discussions at the conference aim to chart the path forward for using NAMs in chemical safety testing with a focus on aggressively reducing the use of animal testing.

## NAMs Work Plan Implementation and Validation Update

### Rusty Thomas (U.S. EPA): Day 1 Overview and NAMs Work Plan Progress Update

Dr. Rusty Thomas started the conference by reviewing the overarching goals of the NAMs Work Plan and discussed that one objective of these conferences was for EPA to share progress towards meeting the deliverables and timeline in the Work Plan. He reported on the status of Work Plan deliverables, including metrics on animal use at EPA, recent EPA Science to Achieve Results (STAR) grant awards, partnerships with external organizations related to increasing confidence in the use of NAMs, development of relevant case studies, and the implementation of training programs.

Summary

- The Work Plan, originally released in 2019, aims to develop baselines and metrics, evaluate regulatory flexibility, establish scientific confidence, demonstrate applications, address information gaps, and engage with stakeholders with the aim of reducing animal testing and research while still adhering to the mission of the Agency to protect human health and the environment. An updated Work Plan was released in December 2021, which expanded the species covered to be consistent with TSCA to include all vertebrates and which also included updated deliverable timelines.
- Dr. Thomas presented a high-level overview of the status of specific Work Plan deliverables which included:
  ○ Releasing a report on a review of existing statutes, programmatic regulations, policies, and guidance that relate to vertebrate animal testing and the implementation and use of appropriate NAMs for regulatory purposes (originally projected to be complete in 2022 but finished in 2024).
  ○ Reporting annual progress and summary metrics on reducing vertebrate animal testing requests and use (annually since 2022).
  ○ Finishing a National Academies of Sciences, Engineering, and Medicine (NASEM) study that evaluated the variability and relevance of existing mammalian toxicity tests and reviewed frameworks for validation and establishing scientific confidence in testing methods (2023).
  ○ Developing a scientific confidence framework to evaluate the quality, reliability, and relevance of NAMs (end of 2024).
  ○ Developing an initial set of reporting templates that may be used by EPA and stakeholders to capture the range of specific NAMs used for Agency decisions (end of 2024).
  ○ Ongoing development of case studies for evaluating application to risk assessment and demonstrating protection of human health and the environment.
  ○ Releasing the EPA Strategic Research Action Plans (StRAPs) outlining research products to develop and apply NAMs.
  ○ Encouraging development of NAMs through mechanisms such as the STAR program and facilitating partnerships with organizations focused on establishing scientific confidence in alternative methods.
  ○ Publishing the EPA website to house information about NAM efforts and progress against the Work Plan, ongoing public webinars, peer reviews on deliverables from the Work Plan where appropriate, completing a NAMs pilot training program that will continue to expand, and providing regular scientific exchanges and progress updates through Agency-sponsored and partner-organized events.
- Dr. Thomas presented data showing the metrics on animal use for the Office of Research and Development (ORD) and Office of Pesticide Programs (OPP) from Fiscal Year (FY) 2019 to FY 2023. ORD had a significant reduction in use of mammals from 2019 to 2021 due to ORD reorganization, laboratory remodeling and the coronavirus pandemic, but in FY23 animal use is almost back to the baseline levels established as the average of FY 2016 – 2018. A method for more accurately counting amphibian and other nonmammalian vertebrates in addition to mammals has recently been developed and ORD will work to establish an updated baseline after data have been collected over multiple years. OPP had varying animal usage with no timeline trend, but the data reflect the submissions received. Beginning in 2023, OPP expanded its tracking of data waivers granted for the acute “6-pack”. The use of waivers and NAMs as part of data packages is welcome.
- Dr. Thomas summarized the results of the EPA report which reviewed statutes and regulations to identify the flexibility of incorporating NAMs and to identify barriers and opportunities for implementation. The report found that the relevant statutes are fairly broad and would allow the use of NAMs as long as EPA is using the best available science. Some EPA regulations currently require a minimum set of vertebrate animal testing for decision making.
- EPA has awarded several STAR grants to various institutions since 2019 to advance alternatives to vertebrate animal testing and to develop innovative approaches to test chemicals. EPA will announce new awards for Advancing Sustainable Chemistry soon.
- Partnerships with external organizations continue to be formed to help establish scientific confidence in NAMs. Examples of these partnerships include collaborating with four external organizations on an inter-laboratory pre-validation study of a human thyroid microtissue assay, partnering with five external organizations on the development and validation of 17 assays for developmental neurotoxicity (DNT), co-leading an Organisation for Economic Cooperation and Development (OECD) activity to update Guidance Document (GD) 34, collaborating with National Toxicology Program (NTP) Interagency Center for the Evaluation of Alternative Toxicological Methods (NICEATM) to catalog characteristics of OECD Test Guideline (TG) validation studies, participating in the National Institutes of Health (NIH) Complement Animal Research in Experimentation (Complement-ARIE) program, and co-authoring an Interagency Coordinating Committee on the Validation of Alternative Methods (ICCVAM) report in 2024.
- Dr. Thomas highlighted six case studies evaluating the application of NAMs to risk assessment and demonstrating protection of human health and the environment, five of which were case studies being performed through the inter-governmental Accelerating the Pace of Chemical Risk Assessment (APCRA) consortium. Case study topics include using bioactivity for screening level risk assessment, applying in vitro toxicokinetics (TK) to regulatory decisions, and developing quantitative structure use relationship models for predicting chemical functional use.
- Dr. Thomas described the NAMs training pilot program and trainings already completed to date (e.g., ECOTOX Knowledgebase, Generalized Read Across). He provided information about where to find the resources, including past video trainings,^2^ and announced that EPA will host multiple additional trainings in the coming year.
- To conclude, Dr. Thomas reviewed the agenda for the rest of the day by first describing how the topics were chosen based on a survey from stakeholders and then describing the agenda at a high level and thanking the organizing team members.

Questions answered during the conference included:

- (Verbal, in-person) Jon Arnot (ARC Arnot Research and Consulting): Considering the unique biological and TK properties of avian species, is there potential within the vertebrate NAMs development space to include testing and developing NAMs specifically for birds?
  ○ (Verbal, in-person) Rusty Thomas: EPA is working on avian NAMs primarily in the Great Lakes Toxicology and Ecology Division in Duluth, Minnesota. EPA is mostly focused on the impact of per- and polyfluoroalkyl substances (PFAS) on avian species in field studies. However, efforts are more focused on fish and amphibians [and mammals] than avian species at this time.
- (Online chat) Marc Williams (Defense Health Agency): Did the COVID-19 pandemic contribute to the dampened use of animals reported for 2020 and 2021; i.e., disrupted laboratory studies and an apparent but not “real” reduction in animals in lab studies?
  ○ (Online chat) Christina Baghdikian (U.S. EPA): Hi Marc- More information on the metrics can be found here: https://www.epa.gov/chemical-research/new-approach-methods-nams-animal-use-metrics-research-and-development.
- (Online chat) Kristie Sullivan (Institute for In Vitro Sciences): Regarding the numbers of animals used by ORD, is there any granularity as to what those animals are used for? Can this information be shared publicly?
  ○ (Online chat) Christina Baghdikian (U.S. EPA): Hi Kristie- More information on the metrics can be found here: https://www.epa.gov/chemical-research/new-approach-methods-nams-animal-use-metrics-research-and-development. Note that page has ORD metrics and there’s a link to the OCSPP metrics.
- (Online chat) Zachary (unknown surname and affiliation): Are the external organizations that the EPA is partnering with posted publicly?
  ○ (Online chat) Christina Baghdikian (U.S. EPA): Formal agreements between CCTE and others are listed here https://www.epa.gov/chemical-research/collaborative-agreements-computational-toxicology-research.
- (Online chat) Marc Williams (Defense Health Agency): Could I ask Dr. Thomas if there are exemplar Case Studies where NAMs have been successfully integrated into the risk assessment process?
  ○ (Online chat) Monica Linnenbrink (U.S. EPA): Hi Marc! Thank you for your question. Here are some examples. EPA using NAMs for Endocrine Disruption Screening Program https://www.epa.gov/sciencematters/epa-research-contributes-using-alternatives-screen-chemicals-endocrine-disruption and Developmental Neurotoxicity - https://www.epa.gov/sap/use-new-approach-methodologies-nams-derive-extrapolation-factors-and-evaluate-developmental. TSCA New Chemicals Research Collaboration https://www.epa.gov/reviewing-new-chemicals-under-toxic-substances-control-act-tsca/new-chemicals-collaborative. More information about these examples and additional examples are available in this report https://ntp.niehs.nih.gov/sites/default/files/2024-09/2022-2023_ICCVAMBienRpt_FD_508.pdf.
- (Online chat) Maria Hegstad (Inside EPA): If I recall rightly, the current (2021) NAMs workplan was written for activities through 2024. Is another NAMs workplan update in the works?
  ○ (Online chat) Monica Linnenbrink (U.S. EPA): Thank you for the question, Maria! We are focused on completing the deliverables in the current work plan. As we complete the deliverables, we will discuss the next steps for the EPA NAMs work plan.
- (Online chat) Anonymous virtual attendee: I may have missed it - if so, I apologize - is there an update on progress with the New Chemicals Collaborative Research Program?
  ○ (Online chat) Monica Linnenbrink (U.S. EPA): Since EPA launched the program in February 2022, a public meeting in April 2022 provided an overview of the program and gave the public the opportunity to provide feedback. A 2023-2026 research plan was reviewed by the Board of Scientific Counselors in October 2022 with a final report posted in early 2023. EPA responded to the feedback from this review and it is available https://www.epa.gov/system/files/documents/2023-12/2022_october_bosc_nccrp_report_final_eparesponse_0.pdf. EPA is currently moving forward with the implementation. To date, the program has advanced multiple research objectives, including publications of research evaluation of chemical and analogue approaches, cheminformatics-driven selection of chemicals to include in an in vitro NAM proof of concept, and the beginning of screening work on that proof-of-concept.

Questions answered following the conference included:

- (Verbal, in-person) Jon Arnot: Are there opportunities for looking at toxicokinetics of avian species, in vitro biotransformation in particular?
  ○ (Post meeting, written) Rusty Thomas: There are opportunities for developing avian NAMs, particularly in toxicokinetics, and cross-species extrapolation to avian species through application of the EPA Sequence Alignment to Predict Across Species Susceptibility (SeqAPASS). SeqAPASS is intended to be used to extrapolate chemical toxicity knowledge/data from one species to others. This extrapolation is termed cross species extrapolation and is based on the current understanding of a chemical-protein or protein-protein interaction in one species and the collection of lines of evidence indicating a similar interaction in another species is likely to occur. The results from SeqAPASS provide evidence of protein conservation to be used for predictions of chemical susceptibility or pathway conservation across the diversity of species. This is important as the majority of species will never be tested in the laboratory for toxicity though researchers and regulators are interested in understanding the potential for chemical impacts on all species that have potential for exposure in the environment. More information available online: https://seqapass.epa.gov/seqapass/
- (Online chat) Kristie Sullivan (Institute for In Vitro Sciences): Can you talk a little more about the reporting templates? What tools are they envisioned for? How were they developed? How will they be communicated to companies and developers?
  ○ (Post meeting, written) Rusty Thomas: Reporting templates currently being leveraged by EPA include the OECD Harmonized Template 201 (OHT 201) for recording non-apical effects, such as those obtained from in vitro testing; OECD GD 211 to describe non-guideline in vitro test methods that are included as assay information within the CompTox Chemicals Dashboard; and the OECD ‘Omics Reporting Framework (OORF) and associated template to report the results from in vitro and in vivo transcriptomics studies.
- (Online chat) Jennifer Sass (Natural Resources Defense Council): Can Dr. Thomas re-show the slide with the list of projects that are now ongoing? I am curious as to which of those have components that include identifying and communicating uncertainties.
  ○ (Post meeting, written) Rusty Thomas: It is not clear whether this question is related to the ongoing NAM partnership activities or the ongoing case studies evaluating application of NAMs. In general, identifying and communicating uncertainties constitute a component in most of the projects and case studies as the uncertainties depend on the context of use.

### Nicole Kleinstreuer (NICEATM): ICCVAM Validation Report and NICEATM Activities

Dr. Nicole Kleinstreuer presented updates from NICEATM and ICCVAM on activities related to biomedical research, validation, and adoption of human-based NAMs. The presentation highlighted activities such as: Complement-ARIE, a collaboration with key partners including the U.S. Food and Drug Administration (FDA) and EPA; the Method Developers Forum (MDF) as a proactive effort to implement new technologies and provide opportunities for NAMs developers to interact with relevant stakeholders; and ongoing NICEATM projects such as updates to the Integrated Chemical Environment (ICE) and various computational tools.

Summary

- Dr. Kleinstreuer presented the ICCVAM and NICEATM activities in the context of the NAMs confidence continuum, which includes developing methods in basic research for biomedical applications that can then go through validation and qualification before being adopted and implemented into regulatory policy.
- She announced that new funding will be available under the Complement-ARIE program. The program will invest approximately $300 million over the next decade in the development, standardization, validation, and implementation of human-based NAMs. Specific goals include understanding human health and disease outcomes across diverse populations, providing insights into specific biological processes and disease states, supporting regulatory use through validation and standardization, and making biomedical research more efficient and effective by complementing existing animal models.
- Dr. Kleinstreuer provided an overview of NICEATM and ICCVAM. She explained how ICCVAM, a collaboration of federal agencies, was established by Congress to reduce reliance on animal models and promote NAMs-based human-relevant approaches. NICEATM is housed at the National Institute of Environmental Health Sciences (NIEHS) and provides operational and scientific support to ICCVAM workgroups. She briefly described how ICCVAM workgroups welcome federal partners to become workgroup members. Workgroups are formed around a specific scope and charge. For example, the validation workgroup drafted and published a new guidance document on validation, qualification, and regulatory acceptance of NAMs.
- Dr. Kleinstreuer introduced the MDF, which facilitates early and frequent interaction between method developers and end users. She described the process of how the MDF works where research partners in the federal government and regulated industries articulate their needs around a particular endpoint and put out a call to method developers to articulate how their NAMs address those needs. The first forum was held in summer 2024 and focused on carcinogenicity. More are planned for spring 2025.
- Dr. Kleinstreuer summarized several ongoing NICEATM projects, noting that the list covers a broad portfolio of work. Examples include developing computational models and workflows to democratize access to computational tools. The efforts she highlighted included OPERA (Open (Quantitative) Structure-activity/property Relationship App) version 2.9, Collaborative Acute Toxicity Modeling Suite (CATMoS) (outputs of which are intended to be the basis of a forthcoming science policy guidance to consider a CATMoS-predicted LD50 value as a line of evidence for potentially waiving the rat study), an open-source chemical grouping workflow in KNIME to take a more informed approach to identifying test compounds that will provide the highest value of information (VOI) in new assays, and using machine learning and large language models (LLMs) for automating study data curation to generate robust and reliable reference data for validation.
- Dr. Kleinstreuer provided an overview of the recent updates and uses of ICE. This included example applications, such as determining risk characterization of triazole fungicides and associating in vitro molecular targets to human biomarker alterations.
- Dr. Kleinstreuer concluded by presenting the in-progress work on a new interactive database of validated/qualified NAMs, Collection of Alternative Methods for Regulatory Application (CAMeRA), which is in development with an Advisory Committee to the Director (ACD) workgroup. She mentioned an upcoming call for feedback from the scientific community about what should be in CAMeRA and how it should be designed.

There were no questions answered during the conference.

Questions answered following the conference included:

- (Online chat) D’Ann Williams (Johns Hopkins University): Does CATMoS include synergistic or multiple compounds in the toxicological assessment?
  ○ (Post meeting, written) Nicole Kleinstreuer: CATMoS does not provide information on potential synergistic effects of ingredients within mixtures but has been favorably assessed by external groups for its ability to predict the LD50 of formulated products by combining the individual component predictions with the GHS (Globally Harmonized System of Classification and Labelling of Chemicals) additivity equation (e.g., Chushak et al. 2020 https://pubs.acs.org/doi/abs/10.1021/acs.chemrestox.0c00256).

### Alison Harrill (U.S. EPA): Building Confidence in NAMs via Validation Standard Setting in a Revised OECD GD 34

Dr. Alison Harrill presented on updating OECD Guidance Document (GD) 34 to include modern in vitro and in silico approaches, emphasizing the need for standardized protocols and benchmarks. The presentation also highlighted the role of international collaboration, the Mutual Acceptance of Data (MAD) system in ensuring data acceptance across participating countries, and the use of Value of Information (VOI) frameworks to contextualize the socioeconomic benefits of new testing methods. The goal is to streamline the validation process and build scientific support for new methods.

Summary

- Dr. Harrill introduced OECD GD 34 on Validation and International Acceptance of New or Updated Test Methods for Hazard Assessment. Efforts to revise the GD started in 2023 to address changes in NAMs technologies and best practices for validation and have been led by the Joint Research Centre (JRC), the Netherlands, and key contributors from the U.S., including Dr. Harrill, Nicole Kleinstreuer, Warren Casey (NIEHS), and Charles Kovatch (EPA).
- The OECD defines validation as a process based on scientifically sound principles, establishing the reliability and relevance of a test method for a specific purpose, and emphasizes flexibility, adaptability, and performance demonstration using reference chemicals. OECD Test Guidelines (TG) are based on Mutual Acceptance of Data (MAD), meaning all participating countries agree to use data from an official TG for their risk assessment. Building international scientific support requires consensus on the validation program for a method.
- Dr. Harrill described how a working group is being used to build international scientific support for revisions to GD 34. These are focusing on establishing readiness criteria, modernizing approaches to transferability studies, and special considerations for Defined Approaches.
- Dr. Harrill emphasized the need to update GD 34 because it currently has repetitive language and outdated steps, such as pre-validation and validation steps, which the team aims to streamline. The proposed new, streamlined process has seven steps: standardizing materials, assessing assay relevance and performance benchmarks, technical characterization assessment, within-lab and between-lab reproducibility studies, qualification to assess reliability and relevance for context of use, finalization of the test protocol, and recommendations for or against proposed regulatory use.
- Dr. Harrill then described how validation efforts are typically performed for OECD TGs starting with transferability studies.
  ○ Transferability studies are performed across multiple labs to assess variability, with fewer labs required for in vitro studies compared to in vivo studies, and reference chemical lists are used to assess method performance. She also noted that not all OECD TGs have undergone method reliability studies because they predated GD 34.
  ○ Data from TGs covering vertebrate and invertebrate species show differences in the number of chemicals used in validated studies, with in vitro human health studies requiring more chemicals than in vivo studies, likely due to a lack of appropriate benchmarks.
- Dr. Harrill shared that EPA is focusing on case studies to establish benchmarks for reliability and relevance, considering questions about between-lab validation versus standardization, human relevance compared to gold standard tests, and reliability of assay results compared to traditional approaches. EPA is assessing cross-species concordance using rodent data as surrogates for human data, with pharmaceutical drug data used to compare doses and effects across species.
  ○ Dr. Harrill presented how EPA is using pharmaceutical data to assess the qualitative (hazard) and quantitative (dose matching) concordance across species since they contain directly linked human and rodent data. For this effort, data were curated from new drug applications (NDAs) submitted to FDA.
  ○ She described how comparisons between human and rodent doses show that there is not a strong concordance between human and rodent data, while rat and mouse data are more dose concordant with each other than with human data.
  ○ Qualitative concordance, such as matching effects across species, shows low positive predictive value but high negative predictive value, which is beneficial for clinical development programs.
  ○ Dr. Harrill mentioned how cross-species concordance was also assessed for pharmaceutical data by the International Consortium for Innovation and Quality in Pharmaceutical Development (IQ Consortium) in 2016, and those conclusions matched EPA’s current conclusions.
- Dr. Harrill next focused on how to use this information to create benchmarks for human relevance for environmental chemicals. She described how the ToxRef in vivo dataset was used to compare rodent values from repeat-dose studies with NAMs to understand variability as a benchmark for NAMs.
  ○ A study by Katie Paul-Friedman and colleagues calculated root mean squared errors for point of departure (POD) estimates across repeated studies, specifically for understanding reproducibility of organ-level effects in animal studies. She said these results can also be used as a benchmark for NAM variability.
- Dr. Harrill presented how EPA’s published VOI framework can be used as a decision-making framework to contextualize trade-offs in uncertainty around the POD, costs, and time to decide between a choice of methods that can lead to informing the decision.
  ○ Dr. Harrill presented a case study on how the VOI was applied to the EPA Transcriptomic Assessment Product (ETAP) to answer the following question: Given that additional toxicity testing data may be beneficial, which toxicity testing methodology and assessment process provides the most value?
  ○ Dr. Harrill showed a comparison between the ETAP and a two-year chronic testing modality. It showed that ETAP takes about one year, whereas the traditional method takes several years, including the time for toxicity testing and assessment.
  ○ Dr. Harrill emphasized the benefit of the EPA VOI consideration of socioeconomic factors to assess return on investment (ROI), such as public health costs and productivity loss, with economists estimating costs for various health conditions like asthma and developmental disorders. She concluded by noting how delays in mitigating exposure to toxic chemicals result in accumulating health care costs, whereas timely mitigation can save significant public health resources; the VOI framework helps balance public health costs and benefits, with case studies showing that the new method (ETAP) often provides the most benefit in various scenarios.

Questions answered and comments made during the conference included:

- (Online chat) Susanne Kolle (BASF): What was the source of the data presented for the validation?
  ○ (Verbal, in-person) Alison Harrill: The data source for this information is the OECD secretariat.
- (Verbal, in-person) Chris Vulpe (University of Florida): When comparing in vitro tests and rodent tests, you talked about specific repeats of the same study and investigator. Was genetic variability that comes with using human cells over rodents considered when analyzing these data?
  ○ (Verbal, in-person) Alison Harrill: The in vivo concordance data that we collected were from published studies across a variety of labs, which means there is likely some genetic diversity within the dataset because there were likely multiple strains used. Even if the inbred strains were standardized, there is some diversity in outbred stocks. Therefore, there is some genetic variation in this dataset (across studies) even though it may not be the same amount of variation found among human populations. Genetic variability has not been systematically assessed for many chemicals.
- (Verbal, in-person) Chris Vulpe (University of Florida): Do you expect more variability in general in human studies? Is it a fair comparison when determining a comparator group?
  ○ (Verbal, in-person) Alison Harrill: It depends on the study design and on the mode of action of the chemical. Some clinical studies are quite large (later stage trials can be hundreds of thousands of patients), so the expectation of precision around points of departure will be robust, but there are other outside variables to consider that may impact the outcomes. These could include gene-environment interactions that lead a subset of individuals to respond differently.
- (Online chat) William Irwin (U.S. EPA): From the EPA RATE [Risk Assessment Training and Experience] training on validity, reproducibility is different from accuracy. Olson et al 2000 pharma data from 12 companies also had some interesting concordance data based on many pharmaceuticals tested in both animals and humans (gold standard), where the goal was to predict hazards in humans.
  ○ Citation referenced: Olson, H. , “Concordance of the Toxicity of Pharmaceuticals in Humans and in Animals,” Regulatory Toxicology and Pharmacology, Volume 32, Issue 1, 2000, Pages 56–67, 10.1006/rtph.2000.1399.11029269
- (Online chat) Richard Becker (American Chemistry Council): Regarding VOI - we recently published “Commentary: Value of information case study strongly supports use of the Threshold of Toxicological Concern (TTC).” it’s open access - at https://www.sciencedirect.com/science/article/pii/S0273230024000357. The return on investment for the TTC was immensely greater than either the traditional repeat tox animal method and the ETAP considered by EPA in their ETAP VOI report.
  ○ (Online chat) Monica Linnenbrink (U.S. EPA): Thank you Rick for sharing the commentary. and we also appreciate you serving as an expert on BOSC [Board of Scientific Counselors] panel reviewing the VOI. As I recall, your feedback during the expert review process included support for the use of TTC. EPA reviewed recommendations received through the BOSC process and the final VOI report is now available - https://www.epa.gov/etap/value-information-voi-case-study-etap.

Questions answered following the conference included:

- (Online chat) Morne van der Mescht (Environment Agency, U.K.): Compared to the cost of not testing a chemical, what is the socioeconomic cost of making a mistake using a method with greater uncertainty?
  ○ (Post meeting, written) Alison Harrill: The VOI framework that has been developed does not specifically address a scenario in which the chemical is not tested; instead, the current framework offers metrics that can allow a decision maker to choose the best option between two different testing methods.
- (Online chat) D’Ann Williams (Johns Hopkins University): How do some of these modeling studies agree with methods used by other countries, such as REACH (Registration, Evaluation, Authorisation and Restriction of Chemicals) in the EU (European Union)?
  ○ (Post meeting, written) Alison Harrill: Thank you for this question. While the VOI case study focused on the ETAP methodology, we can certainly extend the analysis framework to other types of testing methods as a future direction.
- (Online chat) Elaine Faustman (Institute for Risk Analyses and Risk Communication): Have you done your comparisons between human epidemiology studies and NAMs for environmental chemicals of focus for EPA?
  ○ (Post meeting, written) Alison Harrill: This is a much smaller dataset for comparison but could certainly be done. One advantage of comparing to clinical trial data is that more of the experimental variables are controlled or at least accounted for via study design and subject exclusion criteria.
- (Online chat) Clive Roper (Roper Toxicology Consulting Limited): In animal studies, there are many other variables, such as strain, food, water, bedding, handling… Some OECD TGs ask for rodent, let alone strain of rat or mouse. These add to huge variability and are not controlled.
  ○ (Post meeting, written) Alison Harrill: Experimental conditions leading to environmental variability are certainly an important source of interstudy variability in dose-effect estimates.
- (Online chat) Elaine Faustman (Institute for Risk Analyses and Risk Communication): Another response to the question of human variability is the research on the comparison across studies.
  ○ (Post meeting, written) Alison Harrill: Thank you for your comment.
- (Online chat) William Irwin (U.S. EPA): Human tumor clonal cells can have high reproducibility, but many tumor cells have DNA chromosomal aberrations that make human relevance a concern. “Are they still ‘human’?” is a question with these profound chromosomal alterations.
  ○ (Post meeting, written) Alison Harrill: Better characterization of genetic stability of cell lines used for toxicology studies is indeed an important consideration for testing.

## Exposure NAMs

### Kristin Isaacs (U.S. EPA): Development and Application of Exposure New Approach Methodologies in EPA’s ExpoCast Project

Dr. Kristin Isaacs discussed the ways in which NAMs are used in EPA’s Exposure Forecasting (ExpoCast) Project to expand the availability of exposure data for evaluation of thousands of chemicals in commerce. The presentation provided a broad overview of key approaches and outcomes.

Summary

- Dr. Isaacs introduced her presentation on how integrated research and development in high-throughput hazard, TK, and exposure data can link exposures that that cause an effect with exposures that occur in the world to enable risk assessors to more rapidly address public health challenges.
- Overlaying exposure and hazard distributions allow for ranking or binning chemicals in terms of priority. Chemicals in which hazard and exposure distributions are orders of magnitude apart may be a lower priority because there is less risk, whereas those with overlapping distributions but high uncertainty might represent a medium-level risk, and overlapping distributions with low uncertainty might represent a higher risk.
- ExpoCast aims to more fully characterize and represent the exposure distributions to reduce uncertainty. Within complex exposure pathways, contact between receptors and the environmental media is often difficult to measure directly, so exposure NAMs are needed for collecting additional data, extrapolating to fill data gaps, making predictions of exposure, and integrating models to predict potential risk and prioritize chemicals.
- Dr. Isaacs described recent efforts to curate data on how chemicals are used in commerce by collecting general use information from public documents. A new public web tool called the Chemical Exposure Knowledgebase allows for interactive evaluation or exploration of the curated chemicals and product information. The Multimedia Monitoring Database (MMDB) includes harmonized information from different data sources mapped to harmonized chemical identifiers across approximately 30 media categories for more than 3,000 chemicals. These datasets are available through Application Programming Interfaces on EPA’s CompTox Chemicals Dashboard^3^ so the public can build reproducible workflows using the data.
- Dr. Isaacs described how machine learning NAMs are being used to fill gaps for chemicals with limited data, such as the quantitative-structure-use-relationship model, which predicts uses of chemicals.
- Non-targeted analysis (NTA) is being used to identify and evaluate chemicals in environmental and biological samples. EPA is investing in developing tools, databases, and workflows for rapid analysis of a range of environmental samples for chemicals of interest. Dr. Isaacs noted that the current focus is to look at how to quantify concentrations of chemicals in media using quantitative NTA or qNTA, such as by developing methods for selecting appropriate calibration surrogates for each study and quantifying uncertainty from those surrogates.
- Dr. Isaacs described how multiple high-throughput exposure models can be combined in a consensus framework through the Systematic Empirical Evaluation of Models (SEEM). Similar to meteorological predictions, she noted that one can get a better answer when looking across different models and weighting them according to performance. The various exposure models can cover different pathways, chemistries, and assumptions and can be evaluated and calibrated with known data to come up with a consensus approach using Bayesian regression.
- Machine learning and quantitative structure-activity relationship (QSAR) models are used to predict TK data to help inform bioactivity to exposure ratios that then inform risk evaluations, such as for candidates for chemical prioritization under TSCA.
- Dr. Isaacs summarized by stating that exposure, hazard, and TK data are critical inputs to risk-based screening and decision-making.

Questions answered during the conference included:

- (Verbal, in-person) Sayak Mukherjee (Batelle): What overlap did you see between your databases and the ICE data?
  ○ (Verbal, in-person) Kristin Isaacs: The EPA team collaborates with the NIEHS team leading the ICE project. ICE IVIVE and PBPK tools leverage EPA’s High-throughput Toxicokinetics (httk) package^4^ to provide users with an approachable, easy-to-use interface for running analyses.
- (Online chat) D’Ann Williams (Johns Hopkins University): How do you manage predicting exposures in environmental areas where there are limited or no monitoring data? For example, near industrial animal production facilities?
  ○ (Online chat) Jessica Wignall (ICF): We hope Kristin’s presentation provided examples of how to predict exposure when there is little to no exposure data. More information about how to predict exposure is available on EPA’s website - https://www.epa.gov/chemical-research/rapid-chemical-exposure-and-dose-research
- (Online chat) Maria Hegstad (Inside EPA): Dr. Isaacs mentioned the bioactivity exposure ratio approach she described has been used in screening chemicals for prioritization under TSCA. Can anyone provide more details on that? Was the ratio approach used to select any of the candidates for the two most recent rounds of TSCA prioritization?
  ○ (Online chat) Monica Linnenbrink (U.S. EPA): The identification of 2014 TSCA Work Plan chemical substances included consideration of human health hazard as well as information on exposure potential or bioactivity exposure ratio. The approach is described in the EPA Report Proof-of-Concept Case Study Integrating Publicly Available Information to Screen Candidates for Chemical Prioritization under TSCA https://www.ncbi.nlm.nih.gov/books/NBK605713/pdf/Bookshelf_NBK605713.pdf (description starts at the bottom of page 20).

Questions answered following the conference included:

- (Online chat) Nikhil Chivukula (The Institute of Mathematical Sciences, Chennai): In the environment, we are exposed to a variety of chemical stressors. How can we correctly associate an adverse effect with a particular chemical or a group of chemicals in such scenarios?
  ○ (Post meeting, written) Kristin Isaacs: The tools we are building in ExpoCast do not necessarily link exposure to any specific endpoint. However, the data that we are building support an increased understanding of potential exposure sources and pathways, which can ultimately be linked with effects in epidemiological studies. EPA has also proposed a framework, aggregate exposure pathways (AEPs), that facilitates the linking of exposure data with adverse outcome pathway (AOP) information.
- (Online chat) D’Ann Williams (Johns Hopkins University): Are you using industry-derived data as the basis of these models? If so, are you validating those data?
  ○ (Post meeting, written) Kristin Isaacs: In our exposure modeling efforts, we rely on publicly available data about how chemicals are used in commerce (including levels in consumer products). Some of these data are provided by manufacturers. However, we know that reporting of intentionally added ingredients cannot necessarily provide a complete picture of product content. In ExpoCast, we are also developing analytical non-targeted methods to further examine product content. We have published several papers in this area, including efforts to characterize chemicals in recycled materials.
- (Online chat) Elaine Faustman (Institute for Risk Analyses and Risk Communication): If you had to identify two classes of compounds that pose the most difficulty in predicting exposures, what classes would they be and why? How are you addressing these challenges?
  ○ (Post meeting, written) Kristin Isaacs: There are classes of chemicals that are difficult due to their chemistries and those that are difficult due to lack of information about their sources and release. PFAS compounds are both: Our predictive models do not work well for PFAS structures (although CCTE [EPA Center for Computational Toxicology and Exposure] has recently published new structural descriptor sets that may help), and we have very little specific information about the types of PFAS used in consumer products due to confidential business concerns (oftentimes these compounds are reported on safety data sheets as “proprietary fluorosurfactants”). Other challenging compounds are UVCBs (unknown or variable composition, complex reaction products, or biological materials). There are challenges in characterizing their specific chemical components and estimating associated exposures. In ExpoCast, we are also using NTA to develop chemical “fingerprints” for specific consumer products, and we have proposed expanding this approach to UVCBs. We aim to develop a “representative” composition of different UVCBs to be used in exposure assessments when no other specific information is available.

### Kyle Messier (NIEHS): Integrating Geospatial Exposure Models with NAMs to Evaluate Health Risks from Environmental Chemicals

Dr. Kyle Messier presented how classical geospatial methods and modeling can be integrated with NAMs to evaluate health risks from environmental contaminants. The presentation covered the exposome, geospatial exposomics, GeoTox software (designed to facilitate source-to-outcome modeling in geospatial exposomics), and some best practices in software and computational development for addressing complex challenges.

Summary

- The exposome is the exogenous counterpart to endogenous processes like the genome, transcriptome, microbiome, and metabolome. Dr. Messier stated that the goal is to have exposure and risk assessments incorporate both endogenous and exogenous factors.
- Most current methodologies pertaining to exposomics have been focused on internal exposomics. Dr. Messier discussed the strengths of the standard methods using non-targeted analytical chemistry approaches for novel exposure discovery. This method can have high chemical throughput, be individualized, and feed into other ‘Omic measurements. Some limitations include limited sample sizes, cost, batch and lab effects, and the difficulty in understanding the source or timing of the exposure.
- Geospatial exposomics is reframing geospatial exposure modeling as a source-to-outcome cascade with sequential and necessary steps to result in an individual or population health outcome. There are two overarching frameworks that address the source-to-outcome modeling.
  ○ The biological modeling portion is covered by AOP, which tracks biological mechanisms from molecular targets to population outcomes.
  ○ The geospatial portion is covered by AEP, which is a comprehensive analysis of source, external exposure, and internal exposure (including transformation products) and links to AOPs.
  ○ Where the AEP ends is where the AOP begins.
- Dr. Messier introduced GeoTox as a new user-friendly software for source-to-outcome modeling that is currently available on GitHub and will be available soon on the Comprehensive R Archive Network (CRAN). The software has been tested, uses an object-oriented methodology, and is extensible to integrate with other TK models and data sources.
- Dr. Messier reviewed an example of geospatial risk mapping of chemical mixtures in air using the Congestion Mitigation and Air Quality (CMAQ) data and H2A histone family member X (H2AX) Histone Modification assay.
- He provided another example of a multi-assay risk approach for mapping chemical mixtures with 200+ assays based on key characteristics of carcinogens (KCCs). The model quantifies the multi-chemical and multi-assay risk across the population. He presented several North Carolina maps with county risk levels summarized across all of the KCC assays and some maps filtered for specific modes of action.
- Dr. Messier acknowledged several limitations of geospatial exposure models due to geospatial exposure data availability, population uncertainty, TK uncertainty, complexity of mixtures, and data analysis. New methodologies are needed to address these limitations.
- Dr. Messier reviewed some software and computational best practices for reproducibility by ensuring tools and data are well documented and tested. He emphasized the need to ensure compatibility while developing pipelines for complex analysis of environmental health risks.

Questions answered during the conference included:

- (Online chat) Marc Williams (Defense Health Agency): Are you also leveraging the National Aeronautics and Space Administration’s (NASA’s) technically advanced chemical detection technologies, such as highly sensitive photo-acoustic sensors for detecting sub-parts-per-billion levels of chemicals of interest at Langley Research Center (this has important military applications). NASA also offers early warning rapid detection capabilities of chemical precursors using highly sensitive equities and approaches aligned to environmental monitoring, homeland security, chemical “accidents,” etc.
  ○ (Verbal, in-person) Kyle Messier: We are developing some models for criteria air pollutants and hazardous air pollutants. We do use NASA data, which serve as a tremendous resource for earth observations. I don’t know the specific one in this question. We pull in the chemical transport model with hundreds of species of air pollutants, and there are also more direct measurements from satellite observations. In the same place you find the GeoTox package^5^, you can find our R package. We currently pull in 15 data sources and want to expand and democratize ease of access in R to large-scale data products. We use NASA products and moderate resolution imaging spectroradiometer (MODIS) and have made it easier to pull in global and national spatial data.
- (Verbal, in-person) Rusty Thomas (U.S. EPA): Could you comment further on the biggest sources of uncertainty and sensitivity in this work? If propagated, what are the total uncertainty and sensitivity in various counties? What is the biggest source of uncertainty and how big is that uncertainty when propagated?
  ○ (Verbal, in-person) Kyle Messier: Good question. Our first paper gave the unsatisfying answer of “everything.” There was no one dominant figure; with the geospatial aspect, uncertainty can vary by study area. If we’re bringing in National Health and Nutrition Examination Survey (NHANES) data, that could be different in another country without those data. We saw in the first analyses and here with the GeoTox that everything is contributing. There’s no one area to target. We just keep moving on exposure modeling and TK. We could put limits on modeling chemicals though the entire pipeline that meets an overall variability threshold, but instead we have mostly focused on maintaining many chemicals. It also depends on the assay endpoint and how different the risk map could look.

Questions answered following the conference included:

- (Online chat) Anonymous virtual attendee: So, the dose-response data received are for the main drivers of the mixtures?
  ○ (Post meeting, written) Kyle Messier: Sensitivity analyses show all aspects of the GeoTox pipeline can contribute to the overall response and variability of the mapped mixture response. The dose-response parameters certainly play a significant impact but so do the external concentration, TK, and physical and behavioral factors.
- (Online chat) Elaine Faustman (Institute for Risk Analyses and Risk Communication): At the start, you mentioned the various mixture models available. I did not see what models you used in your platform or how you would choose between models?
  ○ (Post meeting, written) Kyle Messier: We use independent action and generalized concentration addition (GCA) with a 2-parameter hill model for each chemical. Future work will integrate our related work on reflected GCA, which allows for 3-parameter hill models in mixture modeling.

### Sin Urban (Maryland Department of Health): Leveraging Non-Targeted High-Resolution Mass Spectrometry to Reveal the Complete PFAS Fingerprint in Maryland

Dr. Sin Urban’s presentation focused on a NAM using high-resolution mass spectrometry (HRMS) and NTA to identify unknown PFAS in Maryland’s drinking water. He also discussed an example of using NTA to investigate a potential poisoning.

Summary

- The mandate of the Environmental Sciences Division of the Maryland Department of Health (MDH) Laboratories is to try to limit or prevent harmful chemical exposures that have the potential to cause disease. The division consists of up to 72 scientists in 15 different sections employing radiochemistry, microbiology, and analytical chemistry to conduct surveillance testing and develop new methods.
- In 2020, Maryland’s Department of the Environment initiated a multi-agency, data-driven response to assess the presence of PFAS in the state. MDH Laboratories were asked to be partners since no labs had PFAS testing capabilities at that time.
- MDH Laboratories implemented, automated, and accredited targeted drinking water methods: EPA Methods 537.1, 533, and 1633.
- MDH tested all the community water systems in Maryland for the presence of PFAS. Positive detect samples were re-sampled for confirmation and source investigation.
  ○ Legacy PFAS were commonly detected in drinking water, likely from firefighting foams, and the source was predominantly groundwater and not surface water.
  ○ Dr. Urban shared a figure that illustrated a geographic pattern of PFAS detection that is related to geology. The southern part of Maryland has confined aquifers that are protected by bedrock or clay, whereas northern Maryland has unconfined or semi-confined aquifers.
  ○ They concluded that 63 water systems (14%) were above the maximum contaminant levels (MCLs).
- Dr. Urban secured a grant from the Centers for Disease Control and Prevention (CDC) through the Association of Public Health Laboratories (APHL) for a High Resolution Mass Spectrometer specifically for environmental testing. The MDH Laboratories collaborated with Dr. Tim Buckley’s group at EPA to develop NTA workflows. The goal was to analyze drinking water samples from the 63 water systems and use NTA to identify all PFAS.
  ○ Dr. Urban presented a diagram of the data analysis workflow and highlighted the importance of quality assurance/quality control (QA/QC) at the data acquisition step and use of an EPA-developed web app to assess QA/QC parameters. Lastly, he pointed out two steps that use vendor-specific libraries and academic tools like FluoroMatch for identifying unknown spectra.
  ○ He noted they had 100% tracer recoveries and 1,029 unique chemical features in drinking water.
  ○ The HRMS NTA was able to detect all 14 PFAS detected using the targeted EPA Method 533, including five of the six regulated PFAS. GenX was not detected.
  ○ The qNTA results achieved sub-part-per-trillion sensitivity, which was comparable to the targeted method.
  ○ An additional 28 unknown PFAS were detected with corresponding Distributed Structure Searchable Toxicity Substance Identifiers (DTXSIDs) identified for all but one.
  ○ Nine of the 14 targeted PFAS and six unknown PFAS were detected in all the contaminated drinking water samples.
- Dr. Urban summarized his findings by noting the NTA workflow is effective in identifying PFAS, Maryland drinking water contains triple the number of PFAS previously thought, and NTA identified ubiquitous and rare unknown PFAS in contaminated water systems. NTA can be used for source identification, comparison to other states, and health implications.
- Dr. Urban additionally shared a case study in which a Maryland resident was poisoned by diet nuts (Nuez de la India) that were bought online and were suspected to be yellow oleander seeds.
  ○ The Maryland Poison Center identified the poisoning and recommended chelation therapy, which ultimately saved the patient’s life.
  ○ The Poison Center reached out to MDH Laboratories for further investigation, which included a targeted FDA method and NTA to chemically fingerprint the product.
  ○ Using HRMS, the chemical fingerprint of the nuts was a near perfect match to the yellow oleander seeds, although they were marketed as candlenuts.
  ○ FDA extended a consumer warning, and there are ongoing efforts to prohibit selling the product in the U.S.

Questions answered during the conference included:

- (Online chat) Anonymous virtual attendee: Are all those new PFAS compounds detected in contaminated water using NTA precursors? Or are some of these new detections environmental transformation products of more well-annotated PFAS?
  ○ (Verbal, in-person) Sin Urban: We do not know yet. It is very early in the process, but it is a powerful approach. We want other states to join in on this, so this is a teachable moment.
- (Verbal, in-person) Miles Crockett (CCTE): There are a few different areas to improve sensitivity of NTA protocols, including quality and size of spectra libraries, accuracy and power of analysis. Which areas do you think have the best avenues toward improving detection?
  ○ (Verbal, in-person) Sin Urban: In my experience, we got better detections than we expected. We used a brand-new instrument. The one used for diet nuts was an old one. That was the biggest difference.

### Carsten Prasse (Johns Hopkins University): Human and Environmental Exposure Framework for Biosolids

Dr. Carsten Prasse’s presentation focused on developing a framework for assessing contaminants in biosolids and their potential risks.

Summary

- Dr. Prasse introduced biosolids as the solid byproducts from sewage treatment. Approximately 5 million dry metric tons are produced every year in the U.S., and half of that is applied to land, with 25% being used in agriculture as fertilizer. He reviewed some benefits of using biosolids as fertilizers, such as improving soil quality, nutrient richness, and diverting waste from landfills or incineration.
- The current federal regulation of biosolid quality focuses on 10 heavy metals and pathogens with no regulations for organic contaminants like PFAS.
  ○ Since biosolids contain many unknown organic compounds, there is a need to develop approaches that aid in the identification of toxic compounds in complex mixtures.
- Dr. Prasse presented an illustration of the project’s objectives to characterize the occurrence, fate, transport, and risks of novel biosolid-associated organic contaminants (BOCs) using different NAMs and HRMS.
- He collected 16 U.S. and three Canadian biosolid samples, and specimens were analyzed and processed using various extraction methods and custom R scripts for QA/QC.
  ○ To align with the national effort, the compounds of interest included those detected in at least 80% of biosolid samples.
  ○ Dr. Prasse shared that detected features were reduced to 451 after QA/QC.
  ○ Using the Schymanski criteria, 92 compounds were identified with high confidence (levels 1 and 2), with 58 compounds not previously reported in biosolids. Most (77.4%) of the detected compounds were excluded because of the lack of known structures.
  ○ Endogenous compounds, pharmaceuticals, and industrial chemicals were the most common functional use categories of the detected compounds.
- In collaboration with ORD, Dr. Prasse used the Hazard Comparison Module (HCM) to identify chronic and acute data for the 92 identified compounds.
  ○ Dr. Prasse described metrics such as hazard, quality, quality-adjusted hazard, and completeness scores that were calculated and used to prioritize the compounds for further evaluation (e.g., ketoconazole, clorophene).
- A target list of compounds underwent further investigation to explore environmental fate and transport.
  ○ Dr. Prasse presented preliminary results from a biodegradation study using soil and biosolid mixtures and shared that 18 of 31 compounds were degraded by more than 15%. Ongoing work is focused on identifying and assessing transformation products formed during degradation. These transformation products can be incorporated into the database and hazard screening tool.
  ○ His team is also evaluating whether compounds in biosolids are taken up by vegetables grown in soil treated with biosolids.
- Dr. Prasse briefly introduced a pilot study focused on the characterization of exposure scenarios and quantification of exposure factors unique to biosolids workers.
- He summarized his presentation by noting that this framework, based on HRMS and hazard assessment tools, is a promising approach for compound prioritization in complex mixtures.
  ○ He noted that the limited number of compounds in reference mass spectral databases is a major challenge.

Questions answered during the conference included:

- (Verbal, in-person) Chris Vulpe (University of Florida): It seems like a lot of these compounds are manufactured. I’m worried about compounds that are anthropogenic. It seems like there’s no requirement on providing mass spectrometry data on anthropogenic compounds. That seems like it could be a requirement when a new compound is made. They could have those data to look at.
  ○ (Verbal, in-person) Carsten Prasse: I love that idea. To my knowledge, this is not part of any regulation. Many of these chemicals have been around a long time, so we don’t have HRMS data with legacy compounds. It would help to have them, but to my knowledge, they are not required.
- (Online chat) Lisa Golding (Commonwealth Scientific and Industrial Research Organization, Australia): Were the concentrations of the compounds identified by NTA in biosolids quantified?
  ○ (Verbal, in-person) Carsten Prasse: Great question. We are working on some quantitative non-target analyses – that is the next step for these 40 compounds. We plan to ask utilities for additional samples to quantify concentrations.
- (Verbal, in-person) Sin Urban (Maryland Department of Health): I thought pesticides had to be registered and standards had to be submitted; I wish we had that for other chemicals. We have this rich regional sampling. Are there differences in regions or commonalities for biosolids?
  ○ (Verbal, in-person) Carsten Prasse: We haven’t looked at that aspect yet. There are a lot of data on what is present in biosolids. In addition to municipal sources, wastewater treatment plants also receive industrial wastewater. There are a lot of differences, but that is a less regional and more facility-to-facility difference.
- (Online chat) Anonymous virtual attendee: If biosolids are contaminated with toxic and potentially toxic compounds, why are they still being used on agricultural fields?
  ○ (Verbal, in-person) Carsten Prasse: I want to make this clear: We don’t yet know whether there are any risks associated with biosolids. EPA provided funding for groups to evaluate whether there are compounds present. Johns Hopkins is evaluating biosolids because they are important fertilizers and, if used, we then don’t need to apply synthetic fertilizers. This provides a valuable resource and diverts waste from incineration and landfilling, which might be required in some states to address PFAS. We are in the beginning of assessing these materials. I am not trying to say that there is risk, but we don’t know if there is with the samples we are looking at.

### Annette Guiseppi-Elie (U.S. EPA): Session Wrap-Up

Dr. Annette Guiseppi-Elie expressed appreciation for the afternoon filled with presentations of thoughtful and applicable research. She thanked Dr. Maureen Gwinn for opening the workshop and Dr. Rusty Thomas for outlining the five goals and providing an excellent summary of the progress made. She acknowledged Drs. Nicole Kleinstreuer and Alison Harrill for presenting their efforts to encourage the use of NAMs by building scientific confidence and enhancing validation processes.

Dr. Guiseppi-Elie shared that the exposure session was included on the agenda because it was a topic of interest identified by external stakeholders when surveyed for potential NAMs conference agenda topics. She emphasized that a key takeaway from Dr. Kristin Isaacs’ presentation was the need for exposure assessments to be on the same footing as toxicity assessments. She agreed that exposure is not trivial and is essential for risk assessment. Dr. Guiseppi-Elie highlighted the development of various tools and models for high-throughput (HT) exposure evaluations and mentioned the importance of case studies in summarizing and applying the research.

She noted that she was unaware of software packages that were under development to model AOPs and AEPs and looked forward to trying out GeoTox’s application and any future collaborations. She discussed the importance of addressing mixtures and geography as part of the cumulative impacts in risk assessments and the need for reproducible pipelines and best practices in software development (as presented by Dr. Messier).

She praised the practical application of research in identifying unknown PFAS in Maryland’s drinking water from Dr. Urban’s presentation and emphasized the importance of collaboration with EPA ORD and other partners. She expressed gratitude for collaborative researchers in the STAR grant program, like Dr. Prasse, to help leverage external activities.

She encouraged attendees to reach out to other researchers and explore further collaborations and stressed the need for coordinated efforts and leveraging partnerships across federal agencies, academia, and other areas. She concluded by thanking all the presenters and attendees for their engagement.

1 https://www.epa.gov/nam

2 https://www.epa.gov/chemical-research/new-approach-methods-nams-training

3 https://comptox.epa.gov/dashboard/

4 https://www.epa.gov/comptox-tools/high-throughput-toxicokinetics-httk-r-package

5 https://niehs.github.io/GeoTox/