# Conference Overview

## Conference Purpose

The purpose of the 2024 U.S. Environmental Protection Agency (U.S. EPA) State of Science on Development and Use of New Approach Methods (NAMs) for Chemical Safety Testing Conference was to engage a cross-sectional mix of stakeholders and scientific experts in a dialogue about using NAMs to evaluate chemicals for potential health effects. The conference consisted of presentations by scientific experts from inside and outside of the Agency to inform attendees on advances in the NAMs field. EPA presenters also provided an update on the deliverables outlined in the EPA NAMs Work Plan. Speakers presented on the state of the science in NAMs related to exposure NAMs, ‘omics, and in vitro to in vivo extrapolation (IVIVE).

As outlined in the EPA NAMs Work Plan, the Agency hosts regular conferences to exchange information and solicit feedback, and this was the fourth such conference. This report summarizes the discussions and presentations that occurred.

## Conference Dates, Location, and Materials

November 5 and 6, 2024

U.S. EPA Conference Center in Research Triangle Park, NC and online via Zoom Webinar

Link to NAMs conference website for agenda and presentations - https://www.epa.gov/chemical-research/epa-nams-conference

## Participant Summary

There were 130 in-person participants and 818 virtual participants at the two-day conference. The participants were from various sectors, including academia, government, and industry.