# Appendix A Acronym List

ACD: Advisory Committee to the Director
ADME: absorption, distribution, metabolism and excretion
AEP: aggregate exposure pathway
AOP: adverse outcome pathway
APCRA: Accelerating the Pace of Chemical Risk Assessment
APHL: Association of Public Health Laboratories
BMD: benchmark dose
BPAC: biological pathway altering concentration
BSA: bovine serum albumin
CAMeRA: Collection of Alternative Methods for Regulatory Application
CATMoS: Collaborative Acute Toxicity Modeling Suite
CCTE: Center for Computational Toxicology and Exposure
CDC: Centers for Disease Control and Prevention
C_free_: freely dissolved concentrations
CMAQ: Congestion Mitigation and Air Quality
Complement-ARIE: Complement Animal Research in Experimentation
CRAN: Comprehensive R Archive Network
DART: developmental and reproductive toxicology
DDI: DNA damage-inducing
DNT: developmental neurotoxicity
DSL: Domestic Substances List
EAS-E: Exposure and Safety Estimation
EFSA: European Food Safety Authority
EPA: Environmental Protection Agency
eSTAR: Emerging Systems Toxicology for the Assessment of Risk
ETAP: EPA Transcriptomic Assessment Product
EU: European Union
ExpoCast: Exposure Forecasting
FBS: fetal bovine serum
FDA: U.S. Food and Drug Administration
FY: Fiscal Year
GCA: generalized concentration addition
GD: Guidance Document
GHS: Globally Harmonized System of Classification and Labelling of Chemicals
HCM: Hazard Comparison Module
HESI: Health and Environmental Sciences Institute
HRMS: high-resolution mass spectrometry
HT: high-throughput
HTTK: high-throughput toxicokinetics
HTTr: high-throughput transcriptomics
IATA: Integrated Approaches to Testing and Assessment
ICCVAM: Interagency Coordinating Committee on the Validation of Alternative Methods
ICE: Integrated Chemical Environment
IQ Consortium: International Consortium for Innovation and Quality in Pharmaceutical Development
iTTC: internal threshold of toxicological concern
IVB: in vitro testing battery
IVIVE: in vitro to in vivo extrapolation
JRC: Joint Research Centre
LDH: lactate dehydrogenase
LLM: large language model
MAD: Mutual Acceptance of Data
MDF: Method Developers Forum
MDH: Maryland Department of Health
MMDB: Multimedia Monitoring Database
MODIS: moderate resolution imaging spectroradiometer
MPS: microphysiological system
NAMs: new approach methods
NASA: National Aeronautics and Space Administration
NASEM: National Academies of Sciences, Engineering, and Medicine
NDA: new drug application
NHANES: National Health and Nutrition Examination Survey
NICEATM: NTP Interagency Center for the Evaluation of Alternative Toxicological Methods
NIEHS: National Institute of Environmental Health Sciences
NIH: National Institutes of Health
NOEL: no observed effect level
NTA: non-targeted analysis
NTP: National Toxicology Program
OASIS: ’Omics for Assessing Signatures for Integrated Safety
OECD: Organisation for Economic Cooperation and Development
OHT: OECD Harmonized Template
OORF: OECD ‘Omics Reporting Framework
OPERA: Open (Quantitative) Structure-activity/property Relationship App
OPP: Office of Pesticide Programs
ORD: Office of Research and Development
PBK: physiologically-based kinetic
PBPK: physiologically-based pharmacokinetic
PBTK: physiologically-based toxicokinetic
PDMS: polydimethylsiloxane
PFAS: per- and polyfluoroalkyl substances
POD: point of departure
PP-LFER: poly-parameter linear free energy relationships
QA: quality assurance
QC: quality control
QIVIVE: quantitative IVIVE
qNTA: quantitative non-targeted analysis
QSAR: quantitative structure-activity relationship
QSPR: quantitative structure-property relationship
REACH: Registration, Evaluation, Authorisation and Restriction of Chemicals
ROI: return on investment
SEBS: styrene-ethylene-butylene-styrene
SEEM: Systematic Empirical Evaluation of Models
SeqAPASS: Sequence Alignment to Predict Across Species Susceptibility
SETAC: Society of Environmental Toxicology and Chemistry
SOP: standard operating procedure
STAR: Science to Achieve Results
StRAP: Strategic Research Action Plan
TG: test guideline
TK: toxicokinetic
ToxCast: Toxicity Forecasting
tPOD: transcriptome point of departure
TSCA: Toxic Substances Control Act
TTC: threshold of toxicological concern
UF: uncertainly factor
UVCBs: unknown or variable composition, complex reaction products, or biological materials
VOI: Value of Information