# 9 REFERENCES

EPA. 2024. Standard Methods for Development of EPA Transcriptomic Assessment Products (ETAPs). EPA/600/X-23/083. Research Triangle Park, NC:U.S. Environmental Protection Agency.