# 6 HUMAN EQUIVALENT DOSE AND TRANSCRIPTOMIC REFERENCE VALUE

## 6.1 POINT OF DEPARTURE

The transcriptomic point-of-departure for the study is 0.121 mg/kg-day. The point-of-departure is defined as the dose at which there were no coordinated transcriptional changes that would indicate a toxicity of concern. The coordinated transcriptional changes used to identify the POD do not necessarily discriminate between specific hazards, adverse or adaptive effects, nor are they used to infer a mechanism or mode of action.

## 6.2 HUMAN EQUIVALENT DOSE

The point-of-departure is scaled to a Human Equivalent Dose (HED) using the interspecies bodyweight dosimetric adjustment factor (DAF) and a reference human body weight of 80 kg (Table 6-1).

Table 6-1 Calculation of the BMDL_HED_ for perfluoro-3-methoxypropanoic acid

Endpoint | Sex | Organ | BMDL (mg/kg-day) | Terminal Rat Body Weight (kg) | Dose Adjustment Factor (DAF) | BMDL_HED_ (mg/kg-day)
Transcriptional changes | Female | Uterus | 0.121 | 0.227 | 0.231 | 0.0279

B M D L_H E D_ = B M D L × (B W_Rat_^1 / 4^)/(B W_Human_^1 / 4^) = 0.121 m g / k g -day × (0.227 k g^1 / 4^)/(80 k g^1 / 4^) = 0.0279 mg/kg-day

The BMDL_HED_ for perfluoro-3-methoxypropanoic acid is 0.0279 mg/kg-day.

## 6.3 TRANSCRIPTOMIC REFERENCE VALUE

The application of uncertainty values follows the guidelines described in the Standard Methods for Development of EPA Transcriptomic Assessment Products (ETAPs) (EPA 2024). The quantitative application of uncertainty factors for Intraspecies Variability (UF_H_), Animal-to-Human Interspecies Variability (UF_A_), Subchronic-to-Chronic Duration Extrapolation (UF_S_), Extrapolation of a Lowest Observed Adverse Effect Level (LOAEL)-to-No Observed Adverse Effect Level (NOAEL) (UF_L_), and Database (UF_D_) are provided in Table 6-2.

Table 6-2 Uncertainty factors used in the calculation of the TRV for perfluoro-3-methoxypropanoic acid

UF_H_ | 10 | A UF_H_ of 10 is applied to account for interindividual variability in the susceptibility of the human population due to both intrinsic and extrinsic factors that can influence the response to dose and the absence of chemical-specific information to assess toxicokinetic and toxicodynamic variability in humans.
UF_A_ | 3 | A UF_A_ of 3 (10^0.5^) is applied to account for uncertainty in characterizing the toxicokinetic and toxicodynamic differences between animals and humans following oral exposure. Cross-species dosimetric adjustment (HED calculation) was performed using default allometric BW^3/4^ scaling between rats and humans. A factor of 3 is applied to account for residual toxicokinetic uncertainty and potential toxicodynamic differences across species.
UF_S_ | 1 | A UF_S_ of 1 is applied due to the use of a transcriptomic POD from the GO biological process class with the lowest median BMD gene set following a 5-day in vivo study. The transcriptomic POD under these conditions has been shown to be concordant with apical/phenotypic PODs from chronic studies.
UF_L_ | 1 | A UF_L_ of 1 is applied because the POD is a BMDL.
UF_D_ | 10 | A UF_D_ of 10 is applied to account for deficiencies and uncertainties in the database.
| 300 | Composite UF = UF_H_ × UF_A_ × UF_L_ × UF_S_ × UF_D_

Using the BMDL_HED_ from the transcriptional changes in the female rat uterus of 0.0279 mg/kg-day (27.9 μg/kg-day), the TRV was calculated based on the following equation:

T R V = (B M D L_H E D_)/((U F_H_ ( 10 ) X U F_A_ ( 3 ) X U F_L_ ( 1 ) X U F_S_ ( 1 ) X U F_D_ ( 10 ))) = (0.0279 m g / k g -day)/(300) = 0.00009 m g / k g -day

The TRV for perfluoro-3-methoxypropanoic acid is 0.00009 mg/kg-day (0.09 μg/kg-day) and is an estimate of a daily oral dose to the human population that is likely to be without appreciable risk of adverse non-cancer health effects over a lifetime. The TRV is derived from a transcriptomic POD with UFs applied to reflect limitations of the data used.