# 5 ANIMAL STUDY

The 5-day in vivo transcriptomic study used in this ETAP was performed consistent with the standard methods outlined in the EPA report Standard Methods for Development of EPA Transcriptomic Assessment Products (ETAPs) (EPA 2024). Animal study parameters are outlined in the Table 5-1.

## 5.1 STUDY PARAMETERS, GROSS OBSERVATIONS, AND SURVIVAL

Table 5-1 Summary of animal study parameters for perfluoro-3-methoxy propanoic acid

Parameter | Value
Species | Rat
Strain | Sprague Dawley
Sex | Males and females
Age | 10 – 12 weeks post acclimation
Sample Size | n = 8 vehicle control; n = 5 treatment group
Route of Exposure | Oral gavage
Vehicle | Deionized water
Doses | 0, 0.01, 0.1, 0.3, 1.0, 3.0, 10.0, 30.0, 100.0, 300.0 mg/kg-day
Dosing Frequency | Once per day
Dosing Duration | 5 days
Sacrifice Time After Last Dose | 24 h
Organs Evaluated | Adrenal gland, brain, heart, kidneys, liver, lung, ovary, spleen, testis, thyroid, thymus, and uterus

One male in the 30 mg/kg-day treatment group did not survive to termination (Table 5-2). One female rat in the 30 mg/kg-day and one female rat in the 300 mg/kg-day treatment group did not survive to termination. One female rat in the 300 mg/kg-day treatment group exhibited abnormal breathing and rales. A second female rat in the 300 mg/kg-day treatment group exhibited rales. All gross observations were noted on Days 5 and 6 on study. Detailed results from the animal study are presented in Appendix II.

Table 5-2 Survival of animals across doses for male and female rats treated with perfluoro-3-methoxypropanoic acid

Sex | Treatment Doses in mg/kg-day (Number of Animals Surviving Through Termination)
Males | 0 (8), 0.01 (5), 0.1 (5), 0.3 (5), 1.0 (5), 3.0 (5), 10.0 (5), 30.0 (4), 100.0 (5), 300.0 (5)
Females | 0 (8), 0.01 (5), 0.1 (5), 0.3 (5), 1.0 (5), 3.0 (5), 10.0 (5), 30.0 (4), 100.0 (5), 300.0 (4)

## 5.2 TRANSCRIPTIONAL CHANGES

Pre-modeling dataset evaluation was performed to determine where there was adequate signal. All tissues passed the analysis of variance (ANOVA) cut-off of at least 1 gene with false discovery rate (FDR) corrected p-value < 0.05 for benchmark dose (BMD) modeling. Based on the pre-modeling probe filtering, the number of differentially expressed probes from male and female rats varied across sex and tissues (Table 5-3).

Table 5-3 Number of differentially expressed probes following exposure to perfluoro-3-methoxypropanoic acid^*^

Tissue | Male | Female
Adrenal Gland | 170 | 327
Brain | 103 | 110
Heart | 252 | 296
Kidney | 540 | 153
Liver | 347 | 158
Lung | 340 | 86
Ovary | NA | 168
Spleen | 163 | 89
Testis | 120 | NA
Thymus | 121 | 419
Thyroid | 277 | 166
Uterus | NA | 183

* Based on Williams Trend test p-value < 0.05 and |Fold-Change| > 1.5.

NA, not available; PMC, did not pass pre-modeling cut-off using one-way ANOVA with FDR corrected p-value < 0.05.

The female uterus had the Gene Ontology (GO) biological process class with the lowest median BMD value across tissues and in both sexes (Fig. 5-1; Table 5-4). The GO biological process class was negative regulation of cell motility (GO:2000146) with a median BMD value of 0.872 mg/kg-day and an associated median BMDL value of 0.121 mg/kg-day (Table 5-4).

Figure 5-1 Accumulation plots of GO biological process classes by median benchmark dose value for each tissue in male (left) and female (right) rats exposed to perfluoro-3-methoxypropanoic acid.

Chart

Table 5-4 Lowest GO biological process class median benchmark dose values across tissues in male and female rats exposed to perfluoro-3-methoxypropanoic acid

Tissue | GO Accession | Gene Ontology Biological Process Class | # of Genes with BMD | BMD (mg/kg-day) | BMDL (mg/kg-day)
Males
Adrenal Gland | GO:0009896 | positive regulation of catabolic process | 3 | 4.68 × 10^1^ | 1.08 × 10^1^
Brain | GO:0033365 | protein localization to organelle | 3 | 3.70 × 10^1^ | 8.35 × 10^0^
Heart | GO:0048608 | reproductive structure development | 3 | 2.80 × 100 | 8.93 × 10^−1^
Kidney | GO:1901568 | fatty acid derivative metabolic process | 3 | 5.76 × 10^1^ | 3.77 × 10^1^
Liver | GO:0006656 | phosphatidylcholine biosynthetic process | 3 | 5.30 × 10^1^ | 3.53 × 10^1^
Lung | GO:0070374 | positive regulation of ERK1 and ERK2 cascade | 3 | 8.45 × 10^1^ | 1.13 × 10^1^
Spleen | GO:0007519 | skeletal muscle tissue development | 3 | 6.30 × 10^1^ | 3.87 × 10^1^
Testis | GO:0090304 | nucleic acid metabolic process | 3 | 4.11 × 10^1^ | 5.63 × 10^0^
Thymus | GO:0010629 | negative regulation of gene expression | 3 | 6.64 × 10^1^ | 4.09 × 10^1^
Thyroid | GO:0071320 | cellular response to cAMP | 3 | 3.85 × 10^1^ | 1.01 × 10^1^
Females
Adrenal Gland | GO:1901655 | cellular response to ketone | 5 | 9.78 × 10^1^ | 5.15 × 10^1^
Brain | GO:1901654 | response to ketone | 3 | 8.09 × 10^1^ | 4.49 × 10^1^
Heart | GO:1901216 | positive regulation of neuron death | 3 | 1.86 × 10^1^ | 3.15 × 10^0^
Kidney | GO:0042594 | response to starvation | 3 | 9.79 × 10^1^ | 7.96 × 10^1^
Liver | GO:0034641 | cellular nitrogen compound metabolic process | 5 | 7.44 × 10^1^ | 4.50 × 10^1^
Lung | GO:0032355 | response to estradiol | 3 | 1.20 × 10^2^ | 5.39 × 10^1^
Ovary | GO:0060612 | adipose tissue development | 3 | 5.80 × 10^0^ | 6.38 × 10^−1^
Spleen | GO:0045597 | positive regulation of cell differentiation | 3 | 1.53 × 10^2^ | 1.10 × 10^2^
Thymus | GO:0060070 | canonical Wnt signaling pathway | 3 | 9.00 × 10^1^ | 4.97 × 10^1^
Thyroid | GO:0045597 | positive regulation of cell differentiation | 3 | 2.06 × 10^2^ | 1.41 × 10^2^
Uterus | GO:2000146 | negative regulation of cell motility | 3 | 8.72 × 10^−1^ | 1.21 × 10^−1^