# 4 LITERATURE SURVEY

## 4.1 DATABASE SEARCH

The databases listed below were searched on December 19, 2022, by an EPA information specialist and the results stored in the Health and Environmental Research Online (HERO) database^1^. The literature search focused only on the chemical name (and synonyms) with no language or date limitations. Full details of the search strategy for each database are presented in Appendix I.

- PubMed (National Library of Medicine)
- Web of Science (Clarivate)
- ProQuest (Clarivate)

Other searches were performed in European Chemicals Agency (ECHA) registration dossiers, EPA ChemView, National Toxicology Program (NTP) database, Organization for Economic Cooperation and Development (OECD) Screening Information Dataset (SIDS) database, and EPA ECOTOX database.

## 4.2 SEARCH RESULTS

No adequate studies were located regarding toxicity of perfluoro-3-methoxypropanoic acid to humans or animals via oral exposure. No human health relevant studies were identified from searches of journal databases (Appendix I). Similarly, no records were identified from searches of ECHA registration dossiers, EPA ChemView, OECD SIDS database, EPA ECOTOX database, or NTP database of finalized reports or in progress studies.

1 EPA’s HERO database is available at: https://hero.epa.gov/hero/