# 3 CHEMICAL IDENTITY AND PHYSICAL PROPERTIES

Table 3-1 Chemical identity and physical-chemical properties of perfluoro-3-methoxypropanoic acid

Property | Value
Chemical structure | Chemical structure
DTXSID | DTXSID70191136
CASRN | 377-73-1
IUPAC name | 2,2,3,3-Tetrafluoro-3-(trifluoromethoxy)propanoic acid
Synonyms | Perfluoro-3-methoxypropanoic acid; 2,2,3,3-Tetrafluoro-3-(trifluoromethoxy)propanoic acid; Perfluoro-4-oxapentanoic acid; Propanoic acid, 2,2,3,3-tetrafluoro-3-(trifluoromethoxy)-Perfluoromethoxypropionic acid; BRN 1795024; PERFLUORO PFMPA; PFMOPrA; PFMPA; PF4OPeA; PF-4O-PeA; PFPE-2
Color/Form | Liquid
Molecular formula | C4HF7O3
SMILES | OC(=O)C(F)(F)C(F)(F)OC(F)(F)F
Molecular weight (g/mol) | 230.038
Density (g/cm^3^ at 20°C) | 1.65^a^
Boiling point (°C) (@ 0.01 mm Hg) | 129^a^
Melting point (°C) | 4.29^a^
LogP: octanol-water | 3.15^a^
Henry’s law constant (atmm^3^/mole at 25°C) | 3.03e-10^a^
Water solubility (mg/L) | 4.78e-2^a^
Vapor pressure (mm Hg) | 3.51^a^

a Predicted from EPA CompTox Chemicals Dashboard (https://comptox.epa.gov/dashboard/chemical/details/DTXSID70191136). Average values presented where available.