# 2 ASSESSMENT REVIEW

The methods for developing the ETAP outlined in this document have been internally reviewed by Office of Research and Development (ORD) scientists and management. The methods have been externally peer reviewed by the EPA Board of Scientific Counselors and subject to public comment (EPA 2024).

All activities and testing in this ETAP are covered under a standard EPA Category A Quality Assurance Project Plan (QAPP). The ETAP has undergone an Audit of Data Quality (ADQ) by an EPA Quality Assurance (QA) team and review by at least two ORD technical experts. This ETAP has followed the methods outlined in the Standard Methods for Development of EPA Transcriptomic Assessment Products (ETAPs) (EPA 2024). Due to the extensive review of the standardized methods and to facilitate the rapid development, execution, and release, this ETAP did not receive independent peer review. The EPA BOSC has endorsed not adding external peer review for individual ETAPs that are the product of a peer reviewed and approved standardized process without assessment or judgments.