# 1 BACKGROUND

EPA Transcriptomic Assessment Products (ETAPs) are developed by the Office of Research and Development (ORD), United States Environmental Protection Agency (EPA) to provide transcriptomic-based reference values (TRV). To the extent possible based on the currently available evidence, the objective of this human health assessment is to provide a TRV with the level of confidence and caveats outlined in the Standard Methods for Development of EPA Transcriptomic Assessment Products (ETAPs) (EPA 2024). The TRV is defined as an estimate of a daily oral dose to the human population that is likely to be without appreciable risk of adverse non-cancer health effects over a lifetime. The TRV is derived from a transcriptomic point-of-departure (POD) with uncertainty factors applied to reflect limitations of the data used. The transcriptomic POD is defined as the dose at which there were no coordinated transcriptional changes that would indicate a potential toxicity of concern. The coordinated transcriptional changes used to identify the POD do not necessarily discriminate between specific hazards, adverse or adaptive effects, nor are they used to infer a mechanism or mode of action. While a TRV is expressly presented as a chronic value in an ETAP, it may also be applicable across other exposure durations of interest including short-term and subchronic. This approach has been previously used by EPA in certain risk assessment applications (e.g., Provisional Peer-Reviewed Toxicity Value [PPRTV] assessments) wherein a chronic non-cancer reference value has been adopted as a conservative estimate for a subchronic non-cancer reference value when data quality and/or lack of duration-relevant hazard and dose response data preclude direct derivation.

The ETAP is intended to be applied to substances with no existing or publicly accessible repeated dose toxicity studies or human evidence suitable for use as a POD and reference value derivation. The assessment is not intended to represent a comprehensive treatise on the chemical. The ETAP is not a risk assessment because it does not include an exposure assessment nor an overall risk characterization. Further, the human health assessment does not address the legal, political, social, economic, or technical considerations involved in risk management. The ETAP can be used by EPA, states, tribes, and local communities, along with specific exposure and other relevant information, to determine, under the appropriate statutes, if, and when, it is necessary to take action to address potential risk associated with human exposures to the ETAP chemical. ETAP assessments may be updated to incorporate new data or methodologies that might impact the reference values, or, retired if traditional toxicity studies and an associated human health assessment are published. The general methods associated with conducting the systematic literature survey and animal study are provided in Standard Methods for Development of EPA Transcriptomic Assessment Products (ETAPs) (EPA 2024).