# 8 APPENDIX II

## 8.1 DETAILED ANIMAL STUDY REPORT PERFLUORO-3-METHOXYPROPANOIC ACID

### 8.1.1 OVERVIEW

Male and female Sprague Dawley rats were exposed via oral gavage for 5 days with nine doses of perfluoro-3-methoxypropanoic acid and a vehicle control. At the end of the exposure period, gene expression changes were measured in the liver, kidney, spleen, thyroid, heart, adrenal gland, ovary (female), testes (male), thymus, uterus (female), brain, and lung. Dose response analyses of the gene expression changes were performed using BMD modeling and the results summarized by GO biological process classes. The GO biological process class with the lowest median BMD value was identified across all the tissues examined in either sex. The median BMDL associated with the identified GO biological process class was selected as the transcriptomic POD and used to derive the TRV.

### 8.1.2 DOSE FORMULATIONS AND PRE-ADMINISTRATION ANALYSIS

#### 8.1.2.1 Chemical Procurement, Purity, Stability, and pH

Perfluoro-3-methoxypropanoic acid was purchased from Synquest Laboratories (Part # 2121-3-66; Lot # 00016952). Identity and purity (> 98%) of the chemical was confirmed at the US EPA using liquid chromatography/tandem mass spectrometry (LC/MS/MS) with electrospray ionization (ESI) in negative ion Information Dependent Acquisition (IDA) mode on a Sciex X500R quadrupole time-of-flight (QTOF) mass spectrometer. Purity of the standard (Figure 8-1) is ≥ 98% by this method and is consistent with the certificate-of-analysis. Perfluoro-3-methoxypropanoic acid eluted at 4.93 min. All other observed signal was observed in the solvent blank.

Figure 8-1 Total ion chromatogram of a 100 μg/mL perfluoro-3-methoxypropanoic acid standard used for purity confirmation.

graph

The concentration and pH stability of perfluoro-3-methoxypropanoic acid was evaluated initially and after 5 days at 4 °C. Perfluoro-3-methoxypropanoic acid solutions were prepared in deionized water at 60.9 mg/mL and 1.89 μg/mL. Solutions were sonicated for 20 minutes to ensure dissolution of the standard. Stability measurements were made immediately after the initial preparation as well as on Day 5. Solutions were stored at 4 °C in the dark between measurements. The solutions were diluted with methanol for measurement of concentration stability by peak area. The stability was determined by LC/MS/MS on a Sciex X500R QTOF using negative ion ESI high resolution-multiple reaction monitoring (HR-MRM) and information dependent acquisition modes. The experiment was performed twice to confirm initial results. The average peak areas were used to calculate an average percent loss less than 10% observed over 5 days. Average percent recovery over 5 days was 98.8 ± 14.1% for the 60.9 mg/mL solution and 93.6 ± 12.5% for the 1.89 μg/mL solution.

Prior to measurement of pH, the 60.9 mg/mL solutions in water were brought to room temperature. A Corning Pinnacle 530 pH meter with FisherBrand Accumet pH probe was used to measure pH. The initial pH of the freshly prepared 60.9 mg/mL solution was 1.03 for Experiment #1 and 0.56 for Experiment #2. The pH was adjusted with 2 M NaOH to 4.40 for Experiment #1 and 4.65 for Experiment #2, both of which were within the targeted 4.5 ± 0.2 pH unit range. The pH on Day 5 was measured to be 6.46 for Experiment #1 and 7.65 for Experiment #2.

#### 8.1.2.2 Dose Selection and Dosing Solution Preparation

At the time of study initiation, perfluoro-3-methoxypropanoic acid did not have any existing acute or repeat dose toxicity studies to assist in identifying the potential dose range in the study. An initial dose-range finding study was performed in male and female rats with dose levels ranging from 1.0 - 1000 mg/kg-day. In both males, some lethality was observed at the highest two doses. In females, some lethality was observed at the high dose. Initial transcriptomic analysis of select tissues demonstrated gene set BMDL’s were at or below the lowest dose. Based on these results, the present study was performed with nine dose levels plus a vehicle control. The high dose was set at 300 mg/kg-day range due to the observed lethality in both sexes. The next seven dose levels were set at half-log10 intervals and lowest dose at a full log10 lower than the eighth dose. The expected and observed concentrations of the dosing solutions are presented in Table 8-1.

Dosing solutions of perfluoro-3-methoxypropanoic acid were prepared by the contracted laboratory (Inotiv, Morrisville, NC) in deionized water and the pH was adjusted with 2 M NaOH to 4.5. Dosing solution concentrations were confirmed at the US EPA. Dosing solutions were diluted with methanol, spiked with 2,3,3,3-tetrafluoro-2-(1,1,2,2,3,3,3-heptafluoropropyl)-^13^C_3_-propanoic acid (^13^C_3_-GenX) as an internal standard, and vortexed to mix. The dilutions were analyzed by LC/MS/MS in ESI negative ion HR-MRM mode on a Sciex X500R QTOF mass spectrometer. The final perfluoro-3-methoxypropanoic acid concentrations for the dosing solutions are presented in Table 8-2.

The perfluoro-3-methoxypropanoic acid concentrations observed in dosing solution dilutions were quantitated using internal standard calibration. The calibration curve included 5 or more points. Calibration for the analyte was acceptable; the Pearson correlation coefficient (r) was ≥ 0.99 and calculated concentrations of calibration standards were within ± 20% of actual, except for the low standard which was acceptable with a readback concentration within ± 30% of actual. The calibration was verified with a second source standard that gave a calculated concentration within ± 20% of actual. Continuing calibration acceptability was verified before and after analysis of approximately 30 or fewer samples and daily by analysis of continuing calibration standards that gave acceptable calculated concentrations within ± 20% of actual.

The samples were prepared and analyzed together in a batch with a matrix blank, laboratory control sample (LCS), and laboratory control sample duplicate (LCSD) spiked at a concentration below the mid-point of the calibration curve. Perfluoro-3-methoxypropanoic acid was not detected above the limit of quantitation (LOQ) in the matrix blank. The LOQ was set at the lowest calibration standard of 30 ng/mL. A laboratory duplicate (LD) of project sample 0.002 mg/mL was also included. The relative percent difference for the LD compared to the project sample was 2.0%. Recoveries for the LCS and LCSD were within the acceptance range of ± 30% of actual.

Table 8-1 Dosing solution concentrations (mg/ml) for perfluoro-3-methoxypropanoic acid

Expected Concentration (mg/ml) | 0.002 | 0.02 | 0.06 | 0.2 | 0.6 | 2 | 6 | 20 | 60.0
Observed Concentration (mg/ml) | 0.00292 | 0.0342 | 0.0864 | 0.274 | 0.737 | 2.90 | 8.85 | 22.8 | 83.7
% Difference^a^ | 37.4 | 52.4 | 36.1 | 31.2 | 20.5 | 36.7 | 38.4 | 13.1 | 33.0

a % Difference = [abs(a − b)/(a+b)/2] × 100%; where a is the expected concentration and b is the observed concentration.

### 8.1.3 ANIMAL HUSBANDRY AND TREATMENT

All procedures in the study were in compliance with the Animal Welfare Act Regulations, 9 CRF 1-4. All animals were treated according to the Guide for the Care and Use of Laboratory Animals. Animals were housed in a facility accredited by the Association for Assessment and Accreditation of Laboratory Animal Care (AAALAC) and maintained at 20-22°C, 30-70% humidity, and a 12:12 h photoperiod (lights off at 1800 hours). Male and female Sprague Dawley rats (8-10 weeks old; Crl:CD(SD)) were received at Inotiv (Morrisville, NC) from Charles River Laboratories (Raleigh NC), housed two per polycarbonate cage (23 cm × 44 cm) with micro-isolator tops and heat-treated hardwood bedding (Northeastern Products Crop., Warrensburg, NY). Rats received food (Certified Purina Pico Chow No. 5002; Ralston Purina Co., St. Louis MO) and reverse osmosis treated tap water (City of Durham, NC) ad libitum. Animals were acclimated for 2 weeks and were uniquely identified by ear punch prior to study start. The animals were assigned to a dose group using a procedure that stratifies animals across groups by body weight, such that the mean body weight of each group is not statistically different from any other group using analysis of variance (ANOVA) (Statistical Analysis System version 9.2, SAS Institute, Cary, NC). Only clinically healthy animals were used for allocation. Five male and female rats per dose group received the test article (0.01, 0.1, 0.3, 1.0, 3.0, 10, 30, 100, and 300 mg/kg-day) solubilized in deionized water and eight males and females received deionized water vehicle alone via gavage at a dose volume of 5 ml/kg for five consecutive days. Dose volumes were adjusted on a daily basis based on individual animal body weights. Dosing solutions were placed on a stir plate at least 30 minutes prior to dosing and continuously stirred. Dosing occurred at the same time each day (±1 hour) and animals were euthanized 24 hours (±1 hour) after the 5th dose. Animals were observed twice daily on weekdays and once daily on weekends. Clinical observations were performed within two days of arrival, when allocating animals to dose groups, prior to first gavage administration, and at termination. Body weights were collected within two days of arrival, when allocating animals to dose groups, prior to each administration, and at termination. Animal studies were performed by Inotiv (Morrisville, NC).

### 8.1.4 GROSS OBSERVATIONS, SACRIFICE, AND TISSUE COLLECTION

Male rats from the lowest six doses survived until scheduled termination (Table 8-2). One male rat in the 30 mg/kg-day treatment group died prior to the scheduled termination. One female rat in the 30.0 and 300 mg/kg-day treatment groups died prior to the scheduled termination. One female rat in the 300 mg/kg-day treatment group exhibited abnormal breathing and rales. A second female rat in the 300 mg/kg-day treatment group had rales. All gross observations were noted on Days 5 and 6 of the study.

Table 8-2 Exposure doses and survival of animals for male and female rats treated with perfluoro-3-methoxypropanoic acid

Sex | Exposure Doses in mg/kg-day (Number of Animals Surviving Through Termination)
Males | 0 (8), 0.01 (5), 0.1 (5), 0.3 (5), 1.0 (5), 3.0 (5), 10.0 (5), 30.0 (4), 100.0 (5), 300.0 (5)
Females | 0 (8), 0.01 (5), 0.1 (5), 0.3 (5), 1.0 (5), 3.0 (5), 10.0 (5), 30.0 (4), 100.0 (5), 300.0 (4)

Surviving animals were sacrificed 24 hours (±1 hour) after administration of the final dose. Rats were euthanized by carbon dioxide asphyxiation and death confirmed by exsanguination. At the time of sacrifice, blood (∼2.0 mL) was collected from each animal at termination using cardiac puncture and placed into a four K3EDTA tubes, centrifuged at 1500 × g for 15 min at 4°C, and the plasma removed. Plasma was stored in six aliquots of 100 μl and frozen at or below −70°C in cryotubes after collection for potential analysis. The time of blood collection and necropsy were recorded for all animals. The left lobe of the liver, kidneys, spleen, thyroid, heart, adrenal glands, ovaries (female), testes (male), thymus, uterus (female), brain, and left lung were removed and preserved for RNA isolation. Necropsies were completed by noon. Animal sacrifice and tissue collection was performed by Inotiv (Morrisville, NC).

### 8.1.5 RNA ISOLATION AND TRANSCRIPTOMIC MEASUREMENTS

The left lobe of the liver, right kidney, spleen, heart, testes (male), thymus, uterus (female), brain, and left lung were removed. Samples from these larger tissues were cubed into ∼5 mm^3^ pieces and divided amongst three cryotubes (except adrenal glands, thyroid, and ovaries, which were split amongst two cryotubes due to small tissue size). Two of the cryotubes contained RNAlater^™^ (ThermoWaltham, MA) while the third cryotube containing from the larger tissue samples was frozen in liquid nitrogen and stored at approximately −80°C. The samples in RNAlater^™^ were stored at room temperature for same-day processing or 4°C until ready for processing to total RNA. Remaining tissues were then stored at approximately −20°C for up to 3 weeks before being transferring to approximately −80°C. Approximately 10 mg of liver and spleen or 20 mg of all other tissues were transferred by a clean single-edged razor blade to a microplate preloaded with 50 μL of RNAlater^™^. Samples were processed for RNA purification using the RNAdvance purification kit (Beckman Coulter). For each plate of tissues in RNAlater^™^, the tissue fragment was transferred from RNAlater^™^ to a dry Kimwipe to remove excess liquid, and then placed into a deep well homogenization microplate preloaded with 400 μL of Lysis Buffer with Proteinase K and containing two stainless steel balls. The homogenization plate was shaken on a plate shaker at an optimized homogenization speed for 10 minutes. After shaking, homogenates were transferred to an RNA purification deep-well microplate and transferred to a 37°C water bath for 25 minutes of incubation. After incubation, homogenates were frozen at approximately −80°C until processing to purified RNA.

RNAs were purified in a semi-automated process using the RNAdvance protocol and a BioMek FX liquid handler. Bead binding buffer containing paramagnetic solid-phase reversible immobilization (SPRI) beads was added under rapid mixing. Following the addition of beads, plates were incubated at room temperature before magnetic bead capture and washing. Nucleic acids were bound to the SPRI beads and cellular material was washed off. The residual DNA was removed enzymatically with DNase, washed multiple times, and the purified RNA was eluted in 40 μL of nuclease-free water. RNA purity and quantity were evaluated using OD 260/230 and OD 260/280 measurements.

An aliquot of each RNA sample from each tissue, was hybridized with the Biospyder TempO-Seq Rat S1500+ Surrogate v1.2 detector oligo pool mix consisting of 2,654 probes. The full probe set details are available under the National Center for Biotechnology Information Gene Expression Omnibus (GEO) accession: GSE260875. Hybridization was followed by nuclease digestion, ligation, and then heat denaturation. An aliquot of each ligation product was then transferred to a multi-well polymerase chain reaction (PCR) amplification microplate and amplified using sample-specific, “barcoded” primer pairs. The amplification products from each sample were then pooled into a single sequencing library and processed with a PCR clean-up kit prior to sequencing. Each sample was sequenced on an Illumina HiSeq 2500 at a target read depth of ∼1 million mapped reads per sample.

### 8.1.6 SEQUENCE ALIGNMENT, SAMPLE NORMALIZATION, AND QUALITY CONTROL

The sequence alignment and sample normalization followed the process outlined in the Standard Methods for Development of EPA Transcriptomic Assessment Products (ETAPs) (EPA 2024). Briefly, each FASTQ file was aligned to the TempO-Seq probe manifest using HISAT2 and imported directly into SAMtools to compute probe-level counts for each individual FASTQ file. Samples were evaluated for quality based on:

- Sequencing depth (i.e., total number of mapped reads). Samples with < 10% of target depth (100,000 mapped reads) were removed from further analysis.
- Fraction of uniquely mapped reads. Samples with < 50% of reads uniquely mapped to known probes were removed from further analysis.
- Probe coverage (i.e., total probes with at least 5 reads). Samples with < 1,200 covered probes were removed from further analysis.

The list of samples removed based on the alignment QC metrics are listed in Table 8-3.

Table 8-3 Samples removed based on QC metrics

Tissue | Animal ID | Sex | Dose Group | QC Issue
Liver | 108 | Male | vehicle | < 50% reads aligned
Heart | 123 | Male | 0.1 mg/kg-day | < 50% reads aligned
Brain | 143 | Male | 10 mg/kg-day | < 50% reads aligned
Adrenal | 149 | Male | 30 mg/kg-day | < 50% reads aligned
Spleen | 150 | Male | 100 mg/kg/day | < 50% reads aligned

Prior to performing downstream gene expression across samples, probe counts for each sample were normalized to adjust for differences in sequencing depth. For each treatment condition in each sex and tissue, raw probe counts for all samples were normalized within each sample as follows:

- All probes with a mean read count < 5 were removed, as these probes lack sufficient signal for reliable analysis.
- Each remaining probe count was normalized to Counts Per Million (CPM) = probe count * 1,000,000 / sum of all remaining probe counts in sample
- CPM values were transformed to log_2_ scale with added pseudo-count of 1 to prevent taking log of zero counts and ensuring a positive value for dose response modeling.

To identify potential outlier samples, a principal component analysis (PCA) was performed on subsets of samples corresponding to either: 1) All samples corresponding to same tissue, and sex, including matched vehicle controls (“treatment PCA”); and 2) All available vehicle controls corresponding to the same tissue and sex (“vehicle PCA”). Samples not meeting the sequencing quality metrics (e.g., < 50% of uniquely aligned reads) were excluded prior to PCA analysis. Outlier samples were identified based on the following considerations:

- Individual samples separated from all remaining samples on either principal component #1 (PC1) or principal component #2 (PC2) by >2x the span of all other samples on the corresponding PC were considered strong outliers and removed from further analysis.
- Individual samples separated by <2x the range of all other samples were considered moderate outliers, and additional exclusion criteria were considered:
  ∘ Vehicle samples that appeared as moderate outliers on both a treatment PCA and vehicle PCA were excluded unless multiple controls from the same group appeared as outliers.
  ∘ Moderate outlier samples with lower quality than corresponding tissue samples by one or more sequencing quality metrics (e.g., percentage of uniquely mapped reads) were excluded.
  ∘ Samples that appeared as moderate outliers in both PC1 and PC2 with a relatively large Euclidean distance from all other remaining samples were excluded.
  ∘ Moderate outlier samples that were especially distant from corresponding replicates or similar doses were excluded.

When multiple outlier samples were present on the same PCA, they were only removed if each outlier sample corresponded to a different dose group, as these were unlikely to represent any reproducible dose-dependent effect. The outlier samples that were removed in the perfluoro-3-methoxypropanoic acid study are listed in Table 8-4. The National Center for Biotechnology Information GEO accession number for the dataset is: GSE260875.

Table 8-4 Samples removed based on PCA grouped by tissue and sex

Tissue | Animal ID | Sex | Dose Group
Spleen | 210 | Female | 300 mg/kg-day
Thyroid | 162 | Female | Vehicle
Adrenal Gland | 128 | Male | 0.3 mg/kg-day
Adrenal Gland | 193 | Female | 10 mg/kg-day
Thymus | 115 | Male | 0.01 mg/kg-day
Thymus | 167 | Female | Vehicle
Brain | 113 | Male | Vehicle
Testis | 131 | Male | 1 mg/kg-day
Ovary | 191 | Female | 3 mg/kg-day
Uterus | 165 | Female | Vehicle

The quality statistics for the remaining sequencing samples are provided in Table 8-5 and Figures 8-2, 8-3, and 8-4.

Table 8-5 Minimum and median TempO-Seq sequencing depth, mapping rate, and probe coverage statistics by tissue and sex

Sample Group | | Sequencing Depth | | Mapping Rate | | Probe Coverage
Tissue | Sex | Minimum | Median | Minimum | Median | Minimum | Median
Liver | Male | 1319890 | 1567787 | 0.904299 | 0.910607 | 1336 | 1566
Liver | Female | 1221565 | 1630937 | 0.883735 | 0.910119 | 1512 | 1627
Kidney | Male | 1214393 | 1373827 | 0.883364 | 0.903278 | 1817 | 1951.5
Kidney | Female | 830736 | 1307532 | 0.872645 | 0.884394 | 1876 | 2029
Spleen | Male | 1170103 | 1525792 | 0.865306 | 0.875215 | 1714 | 1890
Spleen | Female | 973288 | 1224717 | 0.861576 | 0.875101 | 1791 | 1913
Thyroid | Male | 798876 | 1073374 | 0.810685 | 0.851559 | 1906 | 2029
Thyroid | Female | 940246 | 1148191 | 0.785922 | 0.843692 | 1969 | 2044
Heart | Male | 1091511 | 1392526 | 0.851941 | 0.867176 | 1796 | 1948
Heart | Female | 1220552 | 1470762 | 0.824538 | 0.856716 | 1836 | 1977
Adrenal Gland | Male | 1269412 | 1504351 | 0.865419 | 0.881572 | 1808 | 1926
Adrenal Gland | Female | 1023761 | 1550673 | 0.94555 | 0.963216 | 1747 | 1950
Lung | Male | 1074105 | 1348705 | 0.939957 | 0.962015 | 1920 | 2123.5
Lung | Female | 1087649 | 1361548 | 0.935237 | 0.956288 | 2027 | 2144.5
Thymus | Male | 522606 | 1393221 | 0.957296 | 0.965328 | 1664 | 1996
Thymus | Female | 1201274 | 1470065 | 0.958982 | 0.966635 | 1863 | 2011.5
Brain | Male | 883151 | 1281097 | 0.905357 | 0.969901 | 1835 | 2002
Brain | Female | 1106019 | 1336732 | 0.953297 | 0.967818 | 1812 | 2011.5
Testis | Male | 1058842 | 1407276 | 0.962576 | 0.97415 | 1929 | 2030
Ovary | Female | 1029995 | 1681707 | 0.920002 | 0.956569 | 2027 | 2125
Uterus | Female | 1258077 | 1668352 | 0.941067 | 0.956677 | 2006 | 2116

Figure 8-2 Distribution of sequencing depth (number of uniquely mapped reads) for each sample, grouped by tissue and sex.

Chart, scatter chart

Figure 8-3 Distribution of mapping rate (% of reads uniquely aligned to probes) for each sample, grouped by tissue and sex.

A picture containing chart

Figure 8-4 Distribution of probe coverage (number of probes detected with at least 5 reads) per sample, grouped by tissue and sex.

Chart

### 8.1.7 TRANSCRIPTOMIC DATA ANALYSIS AND GO BIOLOGICAL PROCESS SUMMARIZATION

Transcriptomic data analyses and GO biological process summarization were performed as described in the Standard Methods for Development of EPA Transcriptomic Assessment Products (ETAPs) (EPA 2024). The dose response modeling was performed independently on each probe, sex, and tissue using BMDExpress 2.30 BUILD 0488. The digital object identifier (DOI) of the benchmark dose analysis files from BMDExpress and the OECD Omics Reporting Template are: https://doi.org/10.23645/epacomptox.25335844.

### 8.1.8 POINT-OF-DEPARTURE (POD) SELECTION

The GO biological process class with the lowest median BMD value in all tissues and both sexes was the negative regulation of cell motility in the female uterus (0.872 mg/kg-day). The median BMDL of 0.121 mg/kg-day associated with the identified GO biological process class was selected as the POD. The human equivalent median BMDL was used to derive the TRV. The dose response changes of the probes for all 3 genes populating the negative regulation of cell motility GO biological process class are included in Figures 8-5 through 8-7.

Figure 8-5 Dose response model for Cdh1 expression (best model = Exp 4, BMD = 0.534, BMDL = 0.121 in mg/kg-day).

A picture containing graphical user interface

Figure 8-6 Dose response model for Crk expression (best model = Exp 2, BMD = 229.94, BMDL = 148.45 in mg/kg-day).

Graphical user interface with low confidence

Figure 8-7 Dose response model for Cyp1b1 (best model = Exp 4, BMD = 0.872, BMDL= 0.0812 in mg/kg-day).

Chart

## 8.1.9 TERMINAL BODY WEIGHTS

Body weight changes from Day 0 to sacrifice and body weight at sacrifice are provided in Tables 8-6 and 8-7.

Table 8-6 Body weight changes by perfluoro-3-methoxypropanoic acid in male rats

Dose (mg/kg-day) | Body Weight Mean (Std Dev)
| Terminal Body Weight (g) | Body Weight Change (g)
0 | 332.85 ± 34.41 | 30.54 ± 7.02
0.01 | 319.80 ± 23.52 | 28.70 ± 4.41
0.1 | 328.96 ± 16.59 | 34.62 ± 2.92
0.3 | 322.92 ± 18.25 | 30.28 ± 7.21
1.0 | 317.86 ± 26.76 | 28.72 ± 5.61
3.0 | 317.98 ± 20.51 | 30.02 ± 8.11
10 | 320.98 ± 24.85 | 19.62 ± 11.79
30 | 328.78 ± 28.63 | 28.30 ± 3.03
100 | 318.64 ± 19.10 | 20.48 ± 5.64
300 | 327.80 ± 51.00 | 17.08 ± 10.43

Table 8-7 Body weight changes by perfluoro-3-methoxypropanoic acid in female rats

Dose (mg/kg-day) | Body Weight Changes Mean (Std Dev)
| Terminal Body Weight (g) | Body Weight Change (g)
0 | 236.65 ± 27.20 | 9.89 ± 6.46
0.01 | 222.80 ± 16.90 | 2.76 ± 4.41
0.1 | 229.26 ± 15.18 | 5.38 ± 4.88
0.3 | 224.02 ± 9.41 | 4.02 ± 10.74
1.0 | 225.08 ± 24.03 | 5.28 ± 1.72
3.0 | 218.32 ± 25.57 | −2.86 ± 7.50
10 | 236.52 ± 12.88 | 12.28 ± 6.74
30 | 234.20 ± 16.10 | 11.02 ± 4.96
100 | 231.84 ± 12.82 | 11.30 ± 7.23
300 | 212.22 ± 10.18 | −9.60 ± 16.96