# 7 APPENDIX I

## 7.1 POPULATIONS, EXPOSURES, COMPARATORS, AND OUTCOME (PECO) CRITERIA

PECO criteria were used to focus the research questions, search terms, and inclusion/exclusion parameters in the systematic evidence map process. The PECO criteria used for perfluoro-3-methoxypropanoic acid are provided in Table 7-1.

Table 7-1 Summary of PECO elements and associated evidence.

PECO element | Evidence
[underlined: P]opulations | Human: Any population and lifestage (occupational or general population, including children and other sensitive populations).; Animal: Non-human mammalian animal species (whole organism) of any lifestage (including fetal, early postnatal, adolescents and adults).
[underlined: E]xposures | Relevant forms:; [substance X] (CAS number); Other forms of [chemical X] that readily dissociate (e.g., list any salts, etc.).; Known metabolites of interest, including metabolites used to estimate exposures to [chemical X].; Human: Any exposure to [chemical X] via [oral or inhalation] route[s]. Studies will also be included if biomarkers of exposure are evaluated (e.g., measured chemical or metabolite levels in tissues or bodily fluids), but the exposure route is unclear or likely from multiple routes. Other exposure routes, such as those that are clearly dermal, are tracked during title and abstract screening and tagged as “potentially relevant supplemental material.”; Animal: Any exposure to [chemical X] via [oral or inhalation] route[s] of >1 day duration, or any duration assessing exposure during reproduction or development. Studies involving exposures to mixtures will be included only if they include an experimental arm with exposure to [chemical X] alone. Other exposure routes, including [dermal or injection], are tracked during title and abstract as “potentially relevant supplemental material.”
[underlined: C]omparators | Human: A comparison or referent population exposed to lower levels (or no exposure/exposure below detection limits), or exposure for shorter periods of time, or cases versus controls, or a repeated measures design. However, worker surveillance studies are considered to meet PECO criteria even if no statistical analyses using a referent group is presented. Case reports or case series of > 3 people will be considered to meet PECO criteria, while case reports describing findings in 1 –3 people will be tracked as “potentially relevant supplemental material.”; Animal: A concurrent control group exposed to vehicle-only and/or untreated control (control could be a baseline measurement, e.g., acute toxicity studies of mortality, or a repeated measure design).
[underlined: O]utcomes | All health outcomes (cancer and non-cancer). In general, endpoints related to clinical diagnostic criteria, disease outcomes, biochemical, histopathological examination, or other apical/phenotypic outcomes are considered to meet PECO criteria.

## 7.2 LITERATURE SEARCH STRATEGY AND RESULTS

The literature search strategy and search results are summarized in Table 7-2.

Table 7-2 Literature search strategy and search results for perfluoro-3-methoxypropanoic acid

Search | Search Strategy | Date and Results
WOS | TS=“2,2,3,3-Tetrafluoro-3-(trifluoromethoxy)propanoic acid” OR TS=“377-73-1” OR TS=“O=C(O)C(F)(F)C(F)(F)OC(F)(F)F” OR TS=“Perfluoro-3-methoxypropanoic acid” OR TS=“Perfluoro-4-oxapentanoic acid” OR TS=“Propanoic acid, 2, 2, 3, 3- tetrafluoro- 3-(trifluoromethoxy) -” OR TS=“BRN 1795024” OR TS=“Perfluoromethoxypropionic acid” OR TS=“PERFLUORO PFMPA” OR TS=“PF4OPeA” OR TS=“PF-4O-PeA” OR TS=“PFMOPrA” OR TS=“PFMPA” OR TS=“PFPE-2” OR TS=“Propionic acid, 2,2,3,3-tetrafluoro-3-(trifluoromethoxy)-” | 12/19/2022 5 results
PubMed | “2,2,3,3-Tetrafluoro-3-(trifluoromethoxy)propanoic acid”[tw] OR “377-73-1”[tw] OR “377-73-1”[rn] OR “O=C(O)C(F)(F)C(F)(F)OC(F)(F)F”[tw] OR “Perfluoro-3-methoxypropanoic acid”[tw] OR “Perfluoro-4-oxapentanoic acid”[tw] OR “Propanoic acid, 2, 2, 3, 3- tetrafluoro- 3-(trifluoromethoxy) -”[tw] OR “BRN 1795024”[tw] OR “Perfluoromethoxypropionic acid”[tw] OR “PERFLUORO PFMPA”[tw] OR “PF4OPeA”[tw] OR “PF-4O-PeA”[tw] OR “PFMOPrA”[tw] OR “PFMPA”[tw] OR “PFPE-2”[tw] OR “Propionic acid, 2,2,3,3-tetrafluoro-3-(trifluoromethoxy)-”[tw] | 12/19/2022 4 results
ProQuest | ABSTRACT,TITLE(“2,2,3,3-Tetrafluoro-3-(trifluoromethoxy)propanoic acid”) OR ABSTRACT,TITLE(“377-73-1”) OR ABSTRACT,TITLE(“O=C(O)C(F)(F)C(F)(F)OC(F)(F)F”) OR ABSTRACT,TITLE(“Perfluoro-3-methoxypropanoic acid”) OR ABSTRACT,TITLE(“Perfluoro-4-oxapentanoic acid”) OR ABSTRACT,TITLE(“Propanoic acid, 2, 2, 3, 3- tetrafluoro- 3-(trifluoromethoxy) -”) OR ABSTRACT,TITLE(“BRN 1795024”) OR ABSTRACT,TITLE(“Perfluoromethoxypropionic acid”) OR ABSTRACT,TITLE(“PERFLUORO PFMPA”) OR ABSTRACT,TITLE(“PF4OPeA”) OR ABSTRACT,TITLE(“PF-4O-PeA”) OR ABSTRACT,TITLE(“PFMOPrA”) OR ABSTRACT,TITLE(“PFMPA”) OR ABSTRACT,TITLE(“PFPE-2”) OR ABSTRACT,TITLE(“Propionic acid, 2,2,3,3-tetrafluoro-3-(trifluoromethoxy)-”) | 12/19/2022 3 results
Total unique references found | | 5

The five unique references that did not meet PECO criteria are:

1. Miller KE; Strynar MJ. (2022). Improved Tandem Mass Spectrometry Detection and Resolution of Low Molecular Weight Perfluoroalkyl Ether Carboxylic Acid Isomers Environmental Science & Technology Letters 9:747–751. 10.1021/acs.estlett.2c00509 HERO ID: 10584196 (https://hero.epa.gov/hero/index.cfm/reference/details/reference_id/10584196) 36274928
2. Wan Y; Li Z; Huang Z; Hu B; Lv W; Zhang C; San H; Zhang S. (2022). Wafer-Level Self-Packaging Design and Fabrication of MEMS Capacitive Pressure Sensors 10.3390/mi13050738 HERO ID: 10603997 (https://hero.epa.gov/hero/index.cfm/reference/details/reference_id/10603997)
3. Woodlief T; Vance S; Hu Q; Dewitt J. (2021). Immunotoxicity of per- and polyfluoroalkyl substances: Insights into short-chain PFAS exposure Toxics 9:100. 10.3390/toxics9050100 HERO ID: 9959537 (https://hero.epa.gov/hero/index.cfm/reference/details/reference_id/9959537) 34062743
4. Zhang W; Cao H; Liang Y. (2021). Plant uptake and soil fractionation of five ether-PFAS in plant-soil systems Science of the Total Environment 771:144805. 10.1016/j.scitotenv.2020.144805 HERO ID: 9952516 (https://hero.epa.gov/hero/index.cfm/reference/details/reference_id/9952516) 33529820
5. Kometani N; Kaneko M; Morita T; Yonezawa Y. (2008). The formation of photolytic silver clusters in water/supercritical CO2 microemulsions Colloids and Surfaces A: Physicochemical and Engineering Aspects 321:301–307. 10.1016/j.colsurfa.2008.02.005 HERO ID: 5387167 (https://hero.epa.gov/hero/index.cfm/reference/details/reference_id/5387167)

There were no unique references that met PECO criteria and were suitable for use as a POD and reference value derivation.