# ABBREVIATIONS

AAALAC: Association for Assessment and Accreditation of Laboratory Animal Care
ADQ: Audit of Data Quality
ANOVA: Analysis of Variance
BCTD: Biomolecular and Computational Toxicology Division
BMD: Benchmark Dose
BMDL: Benchmark Dose Lower Bound
BW: Body Weight
CASRN: Chemical Abstracts Service Registry Number
CCCB: Computational Chemistry and Cheminformatics Branch
CCED: Chemical Characterization & Exposure Division
CCTE: Center for Computational Toxicology and Exposure
CPAD: Chemical & Pollutant Assessment Division
CPHEA: Center for Public Health and Environmental Assessment
CPM: Counts Per Million
CTBB: Computational Toxicology and Bioinformatics Branch
DAF: Dosimetric Adjustment Factor
DNA: Deoxyribonucleic acid
DTT: Division of Translational Toxicology (formerly Division of the National Toxicology Program)
ECHA: European Chemicals Agency
EPA: U.S. Environmental Protection Agency
ETAP: EPA Transcriptomic Assessment Product
ETTB: Experimental Toxicokinetics and Toxicodynamics Branch
FDR: False Discovery Rate
GEO: Gene Expression Omnibus
GO: Gene Ontology
HED: Human Equivalent Dose
HERO: Health and Environmental Research Online
IDA: Information Dependent Acquisition
IUPAC: International Union of Pure and Applied Chemistry
LC/MS: Liquid Chromatograph Mass Spectrometry
LOAEL: Lowest Observed Adverse Effect Level
NIEHS: National Institute of Environmental Health Sciences
NIH: National Institutes of Health
NOAEL: No Observed Adverse Effect Level
OECD: Organization for Economic Cooperation and Development
ORD: Office of Research and Development
PCA: Principal Component Analysis
PCR: Polymerase Chain Reaction
POD: Point of Departure
QA: Quality Assurance
QAPP: Quality Assurance Project Plan
QTOF: Quadrupole Time-of-Flight
RNA: Ribonucleic acid
SIDS: Screening Information Dataset
SMILES: Simplified Molecular-Input Line-Entry System
SPRI: Solid-Phase Reversible Immobilization
TEAB: Toxic Effects Assessment Branch
ToxValDB: US EPA Chemicals Dashboard ToxVal database
TRV: Transcriptomic-based Reference Value
UF: Uncertainty Factors
WOS: Web of Science