# 5 REFERENCES

Bhat VS, Hester SD, Nesnow S, Eastmond DA. 2013. Concordance of transcriptional and apical benchmark dose levels for conazole-induced liver effects in mice. Toxicol Sci 136:205–215.23970803
Bianchi E, Costa E, Yan ZJ, Murphy L, Howell J, Anderson D, . 2021. A rat subchronic study transcriptional point of departure estimates a carcinogenicity study apical point of departure. Food Chem Toxicol 147:111869.33217531
Cannizzo MD, Wood CE, Hester SD, Wehmas LC. 2022. Case study: Targeted RNA-sequencing of aged formalin-fixed paraffin-embedded samples for understanding chemical mode of action. Toxicol Rep 9:883–894.36518475
Chepelev NL, Gagné R, Maynor T, Kuo B, Hobbs CA, Recio L, . 2017. Transcriptional profiling of male F344 rats suggests the involvement of calcium signaling in the mode of action of acrylamide-induced thyroid cancer. Food Chem Toxicol 107:186–200.28606764
Chepelev NL, Gagné R, Maynor T, Kuo B, Hobbs CA, Recio L, . 2018. Transcriptional profiling of male CD-1 mouse lungs and Harderian glands supports the involvement of calcium signaling in acrylamide-induced tumors. Regul Toxicol Pharmacol 95:75–90.29475067
Clewell HJ, Efremenko A, Campbell JL, Dodd DE, Thomas RS. 2014. Transcriptional responses in the rat nasal epithelium following subchronic inhalation of naphthalene vapor. Toxicol Appl Pharmacol 280:78–85.24976557
Dong H, Gill S, Curran IH, Williams A, Kuo B, Wade MG, . 2016. Toxicogenomic assessment of liver responses following subchronic exposure to furan in Fischer F344 rats. Arch Toxicol 90:1351–1367.26194646
Dunnick JK, Shockley KR, Morgan DL, Brix A, Travlos GS, Gerrish K, . 2017. Hepatic transcriptomic alterations for N,N-dimethyl-p-toluidine (DMPT) and p-toluidine after 5-day exposure in rats. Arch Toxicol 91:1685–1696.27638505
EPA. 1988. Recommendations for and Documentation of Biological Values for Use in Risk Assessment. EPA/600/6-87/008. CinCinnati, OH:U.S. Environmental Protection Agency.
EPA. 1994. Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry. EPA/600/8-90/066F. Research Triangle Park, NC:U.S. Environmental Protection Agency.
EPA. 2000. Risk Characterization Handbook. EPA/100/B-00/002. Research Triangle Park, NC:U.S. Environmental Protection Agency.
EPA. 2002. A Review of the Reference Dose and Reference Concentration Processes. EPA/630/P-02/002F. Washington, DC:US Environmental Protection Agency.
EPA. 2011a. Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. EPA/100/R-11/0001. Washington, DC:U.S. Environmental Protection Agency.
EPA. 2011b. Exposure Factors Handbook. EPA/600/R-09/052F. Washington, DC:U.S. Environmental Protection Agency.
EPA. 2012. Benchmark Dose Technical Guidance. EPA/100/R-12/001. Washington, DC:U.S. Environmental Protection Agency.
EPA. 2014. Guidance for Applying Quantitative Data to Develop Data-Derived Extrapolation Factors for Interspecies and Intraspecies Extrapolation. EPA/100/R-14/002F. Washington, DC:U.S. Environmental Protection Agency.
EPA. 2022. ORD Staff Handook for Developing IRIS Assessments. EPA 600/R-22/268. Research Triangle Park, NC:U.S. Environmental Protection Agency.
EPA. 2024. Scientific Studies Supporting Development of Transcriptomic Points of Departure for EPA Transcriptomic Assessment Products (ETAPs). EPA/600/X-23/084. Research Triangle Park, NC:U.S. Environmental Protection Agency.
Gwinn WM, Auerbach SS, Parham F, Stout MD, Waidyanatha S, Mutlu E, . 2020. Evaluation of 5-day In Vivo Rat Liver and Kidney With High-throughput Transcriptomics for Estimating Benchmark Doses of Apical Outcomes. Toxicol Sci 176:343–354.32492150
Harrill JA, Everett LJ, Haggard DE, Sheffield T, Bundy JL, Willis CM, . 2021a. High-Throughput Transcriptomics Platform for Screening Environmental Chemicals. Toxicol Sci 181:68–89.33538836
Harrill JA, Viant MR, Yauk CL, Sachana M, Gant TW, Auerbach SS, . 2021b. Progress towards an OECD reporting framework for transcriptomics and metabolomics in regulatory toxicology. Regul Toxicol Pharmacol 125:105020.34333066
Howard BE, Phillips J, Miller K, Tandon A, Mav D, Shah MR, . 2016. SWIFT-Review: a text-mining workbench for systematic review. Systematic Reviews 5:87.27216467
Jackson AF, Williams A, Recio L, Waters MD, Lambert IB, Yauk CL. 2014. Case study on the utility of hepatic global gene expression profiling in the risk assessment of the carcinogen furan. Toxicol Appl Pharmacol 274:63–77.24183702
Johnson KJ, Auerbach SS, Costa E. 2020. A Rat Liver Transcriptomic Point of Departure Predicts a Prospective Liver or Non-liver Apical Point of Departure. Toxicol Sci 176:86–102.32384157
Kim D, Langmead B, Salzberg SL. 2015. HISAT: a fast spliced aligner with low memory requirements. Nat Methods 12:357–360.25751142
Kim D, Paggi JM, Park C, Bennett C, Salzberg SL. 2019. Graph-based genome alignment and genotyping with HISAT2 and HISAT-genotype. Nat Biotechnol 37:907–915.31375807
Li H, Handsaker B, Wysoker A, Fennell T, Ruan J, Homer N, . 2009. The Sequence Alignment/Map format and SAMtools. Bioinformatics 25:2078–2079.19505943
Lowe CN, Isaacs KK, McEachran A, Grulke CM, Sobus JR, Ulrich EM, . 2021. Predicting compound amenability with liquid chromatography-mass spectrometry to improve non-targeted analysis. Anal Bioanal Chem 413:7495–7508.34648052
Mansouri K, Grulke CM, Judson RS, Williams AJ. 2018. OPERA models for predicting physicochemical properties and environmental fate endpoints. J Cheminform 10:10.29520515
Mansouri K, Cariello NF, Korotcov A, Tkachenko V, Grulke CM, Sprankle CS, . 2019. Open-source QSAR models for pKa prediction using multiple machine learning approaches. J Cheminform 11:60.33430972
Moffat I, Chepelev N, Labib S, Bourdon-Lacombe J, Kuo B, Buick JK, . 2015. Comparison of toxicogenomics and traditional approaches to inform mode of action and points of departure in human health risk assessment of benzo[a]pyrene in drinking water. Crit Rev Toxicol 45:1–43.
Morgan RL, Whaley P, Thayer KA, Schunemann HJ. 2018. Identifying the PECO: A framework for formulating good questions to explore the association of environmental and other exposures with health outcomes. Environ Int 121:1027–1031.30166065
NASEM. 2007. Toxicity Testing in the 21st Century: A Vision and a Strategy. Washington, D.C.:National Academies of Sciences, Engineering, and Medicine.
NASEM. 2011. Guide for the Care and Use of Laboratory Animals. Washington, DC:U.S. National Academies of Sciences, Engineering, and Medicine.
NTP. 2018. NTP Research Report on National Toxicology Program Approach to Genomic Dose-Response Modeling. NTP-RR-5. Research Triangle Park, NC:National Toxicology Program, U.S. Department of Health and Human Services.
OECD. 2022. OECD Omics Reporting Framework Guidance Document - DRAFT. Paris:Organization for Economic Cooperation and Development.
Phillips JR, Svoboda DL, Tandon A, Patel S, Sedykh A, Mav D, . 2019. BMDExpress 2: enhanced transcriptomic dose-response analysis workflow. Bioinformatics 35:1780–1782.30329029
Recio L, Friedman M, Marroni D, Maynor T, Chepelev NL. 2017. Impact of Acrylamide on Calcium Signaling and Cytoskeletal Filaments in Testes From F344 Rat. Int J Toxicol 36:124–132.28403741
Rowlands JC, Budinsky R, Gollapudi B, Black MB, Wolfinger RD, Cukovic D, . 2013. A genomics-based analysis of relative potencies of dioxin-like compounds in primary rat hepatocytes. Toxicol Sci 136:595–604.24046277
Shockley KR, Cora MC, Malarkey DE, Jackson-Humbles D, Vallant M, Collins BJ, . 2020. Comparative toxicity and liver transcriptomics of legacy and emerging brominated flame retardants following 5-day exposure in the rat. Toxicol Lett 332:222–234.32679240
Thayer KA, Angrish M, Arzuaga X, Carlson LM, Davis A, Dishaw L, . 2022a. Systematic evidence map (SEM) template: Report format and methods used for the US EPA Integrated Risk Information System (IRIS) program, Provisional Peer Reviewed Toxicity Value (PPRTV) program, and other “fit for purpose” literature-based human health analyses. Environ Int 169:107468.36174483
Thayer KA, Shaffer RM, Angrish M, Arzuaga X, Carlson LM, Davis A, . 2022b. Use of systematic evidence maps within the US environmental protection agency (EPA) integrated risk information system (IRIS) program: Advancements to date and looking ahead. Environ Int 169:107363.36057470
Thomas RS, Allen BC, Nong A, Yang L, Bermudez E, Clewell HJ, 3rd, . 2007. A method to integrate benchmark dose estimates with genomic data to assess the functional effects of chemical exposure. Toxicol Sci 98:240–248.17449896
Thomas RS, Clewell HJ, 3rd, Allen BC, Wesselkamper SC, Wang NC, Lambert JC, . 2011. Application of transcriptional benchmark dose values in quantitative cancer and noncancer risk assessment. Toxicol Sci 120:194–205.21097997
Thomas RS, Himmelstein MW, Clewell HJ, 3rd, Yang Y, Healy E, Black MB, . 2013a. Cross-species transcriptomic analysis of mouse and rat lung exposed to chloroprene. Toxicol Sci 131:629–640.23125180
Thomas RS, Wesselkamper SC, Wang NC, Zhao QJ, Petersen DD, Lambert JC, . 2013b. Temporal concordance between apical and transcriptional points of departure for chemical risk assessment. Toxicol Sci 134:180–194.23596260
Yang L, Allen BC, Thomas RS. 2007. BMDExpress: a software tool for the benchmark dose analyses of genomic data. BMC Genomics 8:387.17961223
Zhou YH, Cichocki JA, Soldatow VY, Scholl EH, Gallins PJ, Jima D, . 2017. Editor’s Highlight: Comparative Dose-Response Analysis of Liver and Kidney Transcriptomic Effects of Trichloroethylene and Tetrachloroethylene in B6C3F1 Mouse. Toxicol Sci 160:95–110.28973375