# 4 COMPARISON OF TRANSCRIPTOMIC REFERENCE VALUES WITH TRADITIONAL RfDs

The formal statistical evaluation of the concordance between the traditional and transcriptional results has primarily been focused on the BMD values (EPA 2024). However, since the reference value is ultimately used to evaluate chemical risks, a comparison of available traditional RfD and TRV values provides some understanding of the relative level of protection afforded by the ETAP. In total, seven of the 14 chemicals that were used in the concordance evaluation in the EPA report (EPA 2024; Gwinn et al. 2020) had EPA IRIS, EPA chronic PPRTV, or EPA Office of Water (OW) reference values (Table 4-1). Notably, the critical effect in four of the seven chemicals were in species other than rat, which is the species utilized for ETAP. For six of seven chemicals, the TRV was lower than the RfD or provisional RfD (p-RfD), with perfluorooctanoic acid as the only chemical with a slightly higher TRV (3.1E-05 mg/kg-day versus 2.0E-05 mg/kg-day)^25^. Among the chemicals in Table 4-1, the median absolute ratio^26^ was 2.9 ± 1.4 (Median Absolute Deviation; MAD).

In addition to the seven chemicals used to refine the dose response analysis parameters, a total of 20 additional chemicals were identified from the literature review (EPA 2024) that had EPA Integrated Risk Information System (IRIS) or EPA chronic PPRTV assessments (Table 4-2). A subset of the 20 chemicals had multiple time points, species, or tissues with reported transcriptomic POD values. The transcriptomic POD values were adjusted to an HED using the default body weights for the species, strain, and sex used in the study (EPA 1988). While the study designs and transcriptomic BMD analyses were not standardized as outlined in the preceding methods, the TRV was calculated using the composite UF of 300 to evaluate the general robustness of the approach and provide additional understanding of the relative level of protection that may be afforded by the ETAP. A total of 22 of the 47 combinations used different species for the transcriptomic studies than the study used to derive the RfD or reference concentration (RfC). A total of 28 of the 47 (~60%) combinations had TRVs that were more sensitive than the RfD/RfC; however, the relative sensitivity of the TRVs based on the open literature may be different compared with more standardized methods. The median absolute ratio was 2.3 ± 1.1 (MAD). The maximum absolute ratio was 59-fold for 2,2',4,4'-tetrabromodiphenyl ether where transcriptomic changes were measured in the rat liver after 5 days and the critical effect in the IRIS assessment was neurobehavioral changes in mice following a single dose administration. By comparison, the absolute ratio between the TRV and RfD for 2,2',3,3',4,4',5,5',6,6'-decabromodiphenyl ether was only 1.64-fold even though the transcriptomic changes were also measured in the rat liver after 5 days and the critical effect in the IRIS assessment was also neurobehavioral changes in mice following a single dose. However, the RfD for 2,2',4,4'-tetrabromodiphenyl ether used a composite UF of 3,000 to account for database uncertainties, while the RfD for 2,2',3,3',4,4',5,5',6,6'-decabromodiphenyl ether had only a composite UF of 300. In addition to the bromodiphenyl ethers, the TRV value for naphthalene was approximately 19-fold higher based on the mouse lung compared with the RfC. However, the RfC was based on adverse effects in the nasal epithelium in mice. When the TRV value for naphthalene was based on the nasal epithelium in rats, it was only 1.75-fold higher than the RfC. For those combinations that used different species for the transcriptomic studies, the median absolute ratio was 3.2 ± 1.3 (MAD), while those that used the same species had a median absolute ratio of 1.5 ± 1.1 (MAD). Overall, the results suggest that the TRV provides a similar level of protection relative to the traditional RfD, p-RfD, and RfC values.

Table 4-1 Comparison of Transcriptomic Reference Values (TRV) and Traditional RfD/provisional-RfD (p-RfD) Values for 7 of the 14 Chemicals Used on the Concordance Evaluation

Chemical | TRV (mg/kg-day) | RfD/ p-RfD (mg/kg-day) | TRV-to RfD Ratio | Source, Sex, Species, Study Type
Acrylamide | 1.6E-04 | 2.0E-03 | 0.08 | IRIS 2010^27^; Male Rats; Chronic
Di(2-ethylhexyl) phthalate | 1.1E-02 | 2.0E-02 | 0.55 | IRIS 1987^28^; Female Guinea Pigs; Subchronic-Chronic
Hexachlorobenzene | 2.4E-05 | 8.0E-04 | 0.03 | IRIS 1988^29^; Male and Female Rats; Chronic
Furan | 3.5E-04 | 1.0E-03 | 0.35 | IRIS 1987^30^; Male Mice; Subchronic
Perfluorooctanoic acid | 3.1E-05 | 2.0E-05 | 1.55 | OW 2016^31^; Male Mice; Developmental
Tris(2-chloroisopropyl) phosphate | 6.7E-03 | 1.0E-02 | 0.67 | PPRTV Chronic 2012^30^; Male Mice; Subchronic
Pentabromodiphenyl ether mixture (DE71) | 4.1E-04 | 2.0E-03 | 0.21 | IRIS 1987^33^; Male Rats; Subchronic

Table 4-2 Comparison of Transcriptomic Reference Values (TRV) and Traditional RfD, p-RfD, or RfC Values for 20 Chemicals Identified in the Literature Review

Chemical | TRV (mg/kg-day or mg/m^3^) | Exposure Duration (d) | Sex, Species, Tissue | Reference | RfD or RfC (mg/kg-day or mg/m^3^) | Source, Sex, Species, Study Type | TRV-to-RfD Ratio
Acrylamide | 1.1E-03 | 15 | Male Mice, Lung | (Chepelev et al. 2018) | 2.0E-03 | IRIS 2010^34^, Male Rats, Chronic | 0.55
Acrylamide | 4.9E-04 | 15 | Male Rats, Thyroid | (Chepelev et al. 2017) | 2.0E-03 | IRIS 2010^35^, Male Rats, Chronic | 0.25
Acrylamide | 2.7E-04 | 31 | Male Mice, Hardarian Gland | (Chepelev et al. 2018) | 2.0E-03 | IRIS 2010^36^, Male Rats, Chronic | 0.13
Acrylamide | 1.3E-03 | 31 | Male Rats, Thyroid | (Chepelev et al. 2017) | 2.0E-03 | IRIS 2010^37^, Male Rats, Chronic | 0.67
Acrylamide | 2.4E-03 | 31 | Male Rats, Testis | (Recio et al. 2017) | 2.0E-03 | IRIS 2010^38^, Male Rats, Chronic | 1.20
Allyl alcohol | 6.3E-04 | 1 | Male Rats, Liver | (Johnson et al. 2020) | 5.0E-03 | IRIS 1987, Male Rats, Subchronic | 0.13
Allyl alcohol | 4.2E-04 | 4 | Male Rats, Liver | (Johnson et al. 2020) | 5.0E-03 | IRIS 1987, Male Rats, Subchronic | 0.08
Allyl alcohol | 1.8E-03 | 8 | Male Rats, Liver | (Johnson et al. 2020) | 5.0E-03 | IRIS 1987, Male Rats, Subchronic | 0.37
Allyl alcohol | 3.3E-03 | 15 | Male Rats, Liver | (Johnson et al. 2020) | 5.0E-03 | IRIS 1987, Male Rats, Subchronic | 0.67
Allyl alcohol | 5.0E-03 | 29 | Male Rats, Liver | (Johnson et al. 2020) | 5.0E-03 | IRIS 1987, Male Rats, Subchronic | 1.01
Benzo[a]pyrene | 9.4E-05 | 3 | Male Mice, Liver | (Moffat et al. 2015) | 3.0E-04 | IRIS 2017^39^, Rats, Developmental | 0.31
Benzo[a]pyrene | 9.9E-04 | 28 | Male Mice, Lung | (Moffat et al. 2015) | 3.0E-04 | IRIS 2017^40^, Rats, Developmental | 3.29
Bromobenzene | 7.9E-03 | 1 | Male Rats, Liver | (Johnson et al. 2020) | 8.0E-03 | IRIS 2009^41^, Male Mice, Subchronic | 0.99
Bromobenzene | 6.8E-03 | 4 | Male Rats, Liver | (Johnson et al. 2020) | 8.0E-03 | IRIS 2009^42^, Male Mice, Subchronic | 0.85
Bromobenzene | 3.6E-02 | 5 | Male Rats, Liver | (Thomas et al. 2013b) | 8.0E-03 | IRIS 2009^43^, Male Mice, Subchronic | 4.45
Bromobenzene | 3.4E-03 | 8 | Male Rats, Liver | (Johnson et al. 2020) | 8.0E-03 | IRIS 2009^44^, Male Mice, Subchronic | 0.43
Bromobenzene | 3.6E-02 | 14 | Male Rats, Liver | (Thomas et al. 2013b) | 8.0E-03 | IRIS 2009^45^, Male Mice, Subchronic | 4.46
Bromobenzene | 9.7E-04 | 15 | Male Rats, Liver | (Johnson et al. 2020) | 8.0E-03 | IRIS 2009^46^, Male Mice, Subchronic | 0.12
Bromobenzene | 2.0E-02 | 28 | Male Rats, Liver | (Thomas et al. 2013b) | 8.0E-03 | IRIS 2009^47^, Male Mice, Subchronic | 2.52
Bromobenzene | 3.1E-03 | 29 | Male Rats, Liver | (Johnson et al. 2020) | 8.0E-03 | IRIS 2009^48^, Male Mice, Subchronic | 0.38
Bromobenzene | 4.2E-02 | 90 | Male Rats, Liver | (Thomas et al. 2013b) | 8.0E-03 | IRIS 2009^49^, Male Mice, Subchronic | 5.25
Chloroprene^a^ | 1.4E-02 | 5 | Female Mice, Lung | (Thomas et al. 2013a) | 2.0E-02 | IRIS 2010^50^, Male and Female Rats, Female Mice, Chronic | 0.68
Chloroprene^a^ | 4.7E-02 | 15 | Female Mice, Lung | (Thomas et al. 2013a) | 2.0E-02 | IRIS 2010^51^, Male and Female Rats, Female Mice, Chronic | 2.33
Dichloroacetic acid | 3.5E-02 | 6 | Male Mice, Liver | (Cannizzo et al. 2022) | 4.0E-03 | IRIS 2003^52^, Male and Female Dogs, Subchronic | 8.67
Furan | 6.6E-04 | 21 | Female Mice, Liver | (Jackson et al. 2014) | 1.0E-03 | IRIS 1987^53^, Male Mice, Subchronic | 0.66
Furan | 3.6E-05 | 90 | Male Rats, Liver | (Dong et al. 2016) | 1.0E-03 | IRIS 1987, Male Mice, Subchronic | 0.04
Myclobutanil | 1.8E-02 | 14 | Male Rats, Liver | (Bhat et al. 2013) | 2.5E-02 | IRIS 1988^54^, Male Rats, Chronic | 0.71
Myclobutanil | 2.0E-02 | 14 | Male Rats, Testis | (Bhat et al. 2013) | 2.5E-02 | IRIS 1988^55^, Male Rats, Chronic | 0.81
Naphthalene | 5.8E-02 | 91 | Female Mice, Lung | (Thomas et al. 2011) | 3.0E-03 | IRIS 1998^56^, Male and Female Mice, Chronic | 19.22
Naphthalene^a^ | 5.2E-03 | 91 | Male Rats, Nasal epithelium | (Clewell et al. 2014) | 3.0E-03 | IRIS 1998^57^, Male and Female Mice, Chronic | 1.75
Pronamide | 1.8E-03 | 90 | Male Rats, Liver | (Bianchi et al. 2021) | 7.5E-02 | IRIS 1987^58^, Dogs, Chronic | 0.02
Propiconazole | 2.8E-02 | 30 | Male Mice, Liver | (Bhat et al. 2013) | 1.3E-02 | IRIS 1988^59^, Male Dogs, Chronic | 2.15
p-Toluidine | 5.1E-03 | 5 | Male Rats, Liver | (Dunnick et al. 2017) | 4.0E-03 | PPRTV 2012^60^, Female Rats, Chronic | 1.27
Tetrachloroethylene | 2.5E-02 | 1 | Male Mice, Kidney | (Zhou et al. 2017) | 6.0E-03 | IRIS 2012^61^, Humans, NA | 4.17
Triadimefon | 2.9E-02 | 30 | Male Mice, Liver | (Bhat et al. 2013) | 3.0E-02 | IRIS 1987^62^, Rats, Chronic | 0.96
Trichloroethylene | 1.0E-04 | 1 | Male Mice, Kidney | (Zhou et al. 2017) | 5.0E-04 | IRIS 2011^63^, Mice and Rats, Developmental | 0.20
1,2,3-Trichloropropane | 1.8E-03 | 91 | Female Mice, Liver | (Thomas et al. 2011) | 4.0E-03 | IRIS 2009^64^, Male Rats, Chronic | 0.44
1,2,4-Tribromobenzene | 5.1E-03 | 5 | Male Rats, Liver | (Thomas et al. 2013b) | 5.0E-03 | IRIS 1987^65^, Male Rats, Subchronic | 1.03
1,2,4-Tribromobenzene | 5.1E-03 | 14 | Male Rats, Liver | (Thomas et al. 2013b) | 5.0E-03 | IRIS 1987^66^, Male Rats, Subchronic | 1.03
1,2,4-Tribromobenzene | 6.8E-03 | 28 | Male Rats, Liver | (Thomas et al. 2013b) | 5.0E-03 | IRIS 1987^67^, Male Rats, Subchronic | 1.36
1,2,4-Tribromobenzene | 1.9E-03 | 91 | Male Rats, Liver | (Thomas et al. 2013b) | 5.0E-03 | IRIS 1987^68^, Male Rats, Subchronic | 0.38
2,2',3,3',4,4',5,5',6,6'-Decabromodiphenyl ether | 1.2E-02 | 5 | Male Rats, Liver | (Shockley et al. 2020) | 7.0E-03 | IRIS 2008^69^, Male Mice, Singe dose | 1.64
2,2',4,4'-Tetrabromodiphenyl ether | 5.9E-03 | 5 | Male Rats, Liver | (Shockley et al. 2020) | 1.0E-04 | IRIS 2008^70^, Male Mice, Singe dose | 58.89
2,3,4,6-Tetrachlorophenol | 2.6E-02 | 5 | Male Rats, Liver | (Thomas et al. 2013b) | 3.0E-02 | IRIS 1988^71^, Male and Female Rats, Subchronic | 0.88
2,3,4,6-Tetrachlorophenol | 8.7E-03 | 14 | Male Rats, Liver | (Thomas et al. 2013b) | 3.0E-02 | IRIS 1988^72^, Male and Female Rats, Subchronic | 0.29
2,3,4,6-Tetrachlorophenol | 1.4E-02 | 28 | Male Rats, Liver | (Thomas et al. 2013b) | 3.0E-02 | IRIS 1988^73^, Male and Female Rats, Subchronic | 0.46
2,3,4,6-Tetrachlorophenol | 1.2E-02 | 91 | Male Rats, Liver | (Thomas et al. 2013b) | 3.0E-02 | IRIS 1988^74^, Male and Female Rats, Subchronic | 0.40

a Comparison of the TRV was made to the RfC value since the transcriptomic POD was based on an inhalation exposure.

25 The RfD cited in the table was obtained from the 2016 EPA OW Drinking Water Health Advisory that relied on animal studies in its derivation. An updated interim drinking water health advisory was released in 2022 that relied on human epidemiological studies. For the purposes of evaluating the concordance of the ETAP with the rodent studies, the RfD from the 2016 EPA OW Drinking Water Health Advisory was determined to be the appropriate comparator.

26 The absolute ratio between a and b is defined as maximum{a/b, b/a}.

27 Acrylamide IRIS Assessment: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=286

28 Di(2-ethylhexyl) phthalate IRIS Assessment: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=14

29 Hexachlorobenzene IRIS Assessment: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=374

30 Furan IRIS Assessment: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=56

31 Perfluorooctanoic acid EPA OW Drinking Water Health Advisory: https://www.epa.gov/sites/default/files/2016-05/documents/pfoa_health_advisory_final_508.pdf. The RfD cited in the table was obtained from the 2016 EPA OW Drinking Water Health Advisory that relied on animal studies in its derivation.

32 Tris(2-chloroisopropyl) phosphate PPRTV Assessment: https://cfpub.epa.gov/ncea/pprtv/chemicalLanding.cfm?pprtv_sub_id=1954

33 Pentabromodiphenyl ether IRIS Assessment: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=184

34 Acrylamide IRIS assessment: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=286

35 Acrylamide IRIS assessment: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=286

36 Acrylamide IRIS assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=286

37 Acrylamide IRIS assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=286

38 Acrylamide IRIS assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=286

39 Benzo[a]pyrene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=136

40 Benzo[a]pyrene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=136

41 Bromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1020

42 Bromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1020

43 Bromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1020

44 Bromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1020

45 Bromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1020

46 Bromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1020

47 Bromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1020

48 Bromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1020

49 Bromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1020

50 Chloroprene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1021

51 Chloroprene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1021

52 Dichloroacetic acid IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=654

53 Furan IRIS Assessment: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=56

54 Myclobutanil IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=342

55 Myclobutanil IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=342

56 Naphthalene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=436

57 Naphthalene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=436

58 Pronamide IRIS Assessment: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=95

59 Archived IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=282

60 p-Toluidine PPRTV Assessment at: https://cfpub.epa.gov/ncea/pprtv/recordisplay.cfm?deid=339175

61 Tetrachloroethylene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=106

62 Archived IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=131

63 Trichloroethylene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=199

64 1,2,3-Trichloropropane IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=200

65 1,2,4-Tribromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=196

66 1,2,4-Tribromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=196

67 1,2,4-Tribromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=196

68 1,2,4-Tribromobenzene IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=196

69 2,2',3,3',4,4',5,5',6,6'-Decabromodiphenyl ether IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=35

70 2,2',4,4'-Tetrabromodiphenyl ether IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=1010

71 2,3,4,6-Tetrachlorophenol IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=108

72 2,3,4,6-Tetrachlorophenol IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=108

73 2,3,4,6-Tetrachlorophenol IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=108

74 2,3,4,6-Tetrachlorophenol IRIS Assessment at: https://iris.epa.gov/ChemicalLanding/&substance_nmbr=108