# 1 PURPOSE AND APPLICABILITY

Current estimates of the size of worldwide and domestic chemical inventories are substantial, with increasing trends in future chemical production and release. Relatively few of the chemicals in commerce, as well as those found in the environment, various waste streams, and the human body, have traditional toxicity data or human health assessments. Given historical, current, and future trends in chemical production and the disparity in toxicity testing data and human health assessments, the U.S. Environmental Protection Agency (EPA) is frequently faced with making decisions with limited or no data when evaluating potential human health risks.

This document details the methods used to develop transcriptomic reference values (TRV) for use in EPA Transcriptomic Assessment Products (ETAP) by the Office of Research and Development (ORD), EPA. The scientific rationale underlying ETAP is provided in the EPA report entitled Scientific Studies Supporting Development of Transcriptomic Points of Departure for EPA Transcriptomic Assessment Products (ETAPs) (EPA 2024). The TRV is defined as an estimate of a daily oral dose to the human population that is likely to be without appreciable risk of adverse non-cancer health effects over a lifetime. The TRV is derived from a transcriptomic point of departure (POD)^1^ with uncertainty factors applied to reflect limitations of the data used. The transcriptomic POD is defined as the dose at which there were no coordinated transcriptional changes that would indicate a potential toxicity of concern. The coordinated transcriptional changes used to identify the POD do not necessarily discriminate between specific hazards, adverse or adaptive effects, nor are they used to infer a mechanism or mode of action. While a TRV is expressly defined as a chronic value in an ETAP, it may also be applicable across other exposure durations of interest including short-term and subchronic. This generalization has been previously used by EPA in certain risk assessment applications [e.g., Provisional Peer-Reviewed Toxicity Value (PPRTV) assessments] where a chronic non-cancer reference value has been adopted as a conservative estimate for a subchronic non-cancer reference value when data quality and/or lack of duration-relevant hazard and dose response data preclude direct derivation.

The ETAP is intended to be applied to substances with no existing or publicly accessible repeated dose toxicity studies or human evidence suitable for use as a POD and reference value derivation. The assessment is not intended to represent a comprehensive treatise on the chemical. The ETAP is not a risk assessment because it does not include an exposure assessment nor an overall risk characterization. Further, the human health assessment does not address the legal, political, social, economic, or technical considerations involved in risk management. The ETAP can be used by EPA, states, tribes, and local communities, along with specific exposure and other relevant information, to determine, under the appropriate statutes, if, and when, it is necessary to take action to address potential risk associated with human exposures to a chemical. ETAP assessments may be updated to incorporate new data or methodologies that might impact the estimated reference values or retired if traditional toxicity studies and an associated human health assessment are published.

1 In human health risk assessment practice, a point-of-departure (POD) represents the dose-response point that marks the beginning of a low-dose extrapolation. This point can be the lower bound on dose for an estimated incidence or a change in response level from a dose-response model (e.g., Benchmark Dose; BMD), or a NOAEL or LOAEL for an observed incidence, or change in level of response. For BMD values, this is typically the BMD lower confidence bound (BMDL).