# 6 APPENDIX – STANDARD TEMPLATE

The following pages contain the ETAP Standard Template. The ETAP Standard Template will be used for all ETAP human health assessments.