# ABBREVIATIONS

AAALAC: Association for Assessment and Accreditation of Laboratory Animal Care
ACToR: EPA Aggregated Computational Toxicology Resource
ADME: Absorption, Distribution, Metabolism, and Excretion
ADQ: Audit of Data Quality
ANOVA: Analysis of Variance
ATSDR: Agency for Toxic Substances and Disease Registry
BCTD: Biomolecular and Computational Toxicology Division
BMD: Benchmark Dose
BMDL: Benchmark Dose Lower Confidence Bound
BMDU: Benchmark Dose Upper Confidence Bound
BMR: Benchmark Response
BOSC: EPA Board of Scientific Councilors
CASRN: Chemical Abstracts Service Registry Number
CBI: Confidential Business Information
CCED: Chemical Characterization and Exposure Division
CCTE: Center for Computational Toxicology and Exposure
CPAD: Chemical and Pollutant Assessment Division
CPHEA: Center for Public Health and Environmental Assessment
CPM: Counts Per Million
CTBB: Computational Toxicology and Bioinformatics Branch
DAF: Dosimetric Adjustment Factor
DDEF: Data-Derived Extrapolation Factors
DDEF_AK_: Data-Derived Extrapolation Factor Animal Kinetics
DDEF_HK_: Data-Derived Extrapolation Factor Human Kinetics
DDEF_HD_: Data-Derived Extrapolation Factor Human Dynamics
DSST_ox_: Distributed Structure-Searchable Toxicity
DTT: Division of Translational Toxicology
ECOTOX: EPA Ecotoxicology Knowledgebase
ECHA: European Chemicals Agency
EU JRC: European Union Joint Research Centre
EDTA: Ethylenediaminetetraacetic Acid
EPA: U.S. Environmental Protection Agency
ETAP: EPA Transcriptomic Assessment Product
ETTB: Experimental Toxicokinetics and Toxicodynamics Branch
FDR: False Discovery Rate
GO: Gene Ontology
HAWC: EPA Health Assessment Workspace Collaborative
HED: Human Equivalent Dose
HERO: Health and Environmental Research Online
HH: Human Health
HPV: High Production Volume
HSDB: Hazardous Substances Data Bank
IRIS: Integrated Risk Information System
IUCLID: International Uniform Chemical Information Database
LOAEL: Lowest Observed Adverse Effect Level
LOEL: Lowest Observed Effect Level
MAD: Median Absolute Deviation
MeSH: Medical Subject Heading
NAM: New Approach Methodology
NIEHS: National Institute of Environmental Health Sciences
NIH: National Institutes of Health
NLM HSDB: National Library of Medicine Hazardous Substances Database
NOAEL: No Observed Adverse Effect Level
NOEL: No Observed Effect Level
NTP: National Toxicology Program
OECD: Organisation for Economic Cooperation and Development
ORD: Office of Research and Development
OW: Office of Water
PBPK: Physiologically Based Pharmacokinetic
PCA: Principal Component Analysis
PECO: Population, Exposure, Comparator, and Outcome
PK: Pharmacokinetic
POD: Point of Departure
PPRTV: Provisional Peer-Reviewed Toxicity Value
QA: Quality Assurance
QAPP: Quality Assurance Project Plan
QSAR: Quantitative Structure Activity Relationship
REACH: Registration, Evaluation, Authorisation and Restriction of Chemicals Regulation (EU)
RfC: Reference Concentration
RfD: Reference Dose
RMSD: Root Mean Squared Difference
RNA: Ribonucleic acid
RNA-seq: RNA Sequencing
SEM: Systematic Evidence Map
SIDS: Screening Information Data Set
TEAB: Toxic Effects Assessment Branch
TEST: EPA Toxicity Estimation Software Tool
TD: Toxicodynamic
TK: Toxicokinetic
ToxValDB: US EPA Toxicity Value database
TRI: Toxic Release Inventory
TRV: Transcriptomic Reference Value
UF: Uncertainty Factor
UF_A_: Animal-to-Human Interspecies Uncertainty Factor
UF_D_: Database Uncertainty Factor
UF_H_: Intraspecies Variability Uncertainty Factor
UF_S_: Subchronic-to-Chronic Duration Uncertainty Factor
UF_L_: LOAEL-to- NOAEL Uncertainty Factor