# 7 REFERENCES

Andersen ME, Clewell HJ, 3rd, Bermudez E, Willson GA, Thomas RS. 2008. Genomic signatures and dose-dependent transitions in nasal epithelial responses to inhaled formaldehyde in the rat. Toxicol Sci 105:368–383.18499655
Andersen ME, Clewell HJ, 3rd, Bermudez E, Dodd DE, Willson GA, Campbell JL, . 2010. Formaldehyde: integrating dosimetry, cytotoxicity, and genomics to understand dose-dependent transitions for an endogenous compound. Toxicol Sci 118:716–731.20884683
Baker N, Knudsen T, Williams A. 2017. Abstract Sifter: a comprehensive front-end system to PubMed. F1000Res 6.
Barupal DK, Fiehn O. 2019. Generating the Blood Exposome Database Using a Comprehensive Text Mining and Database Fusion Approach. Environ Health Perspect 127:97008.31557052
Bercu JP, Jolly RA, Flagella KM, Baker TK, Romero P, Stevens JL. 2010. Toxicogenomics and cancer risk assessment: a framework for key event analysis and dose-response assessment for nongenotoxic carcinogens. Regul Toxicol Pharmacol 58:369–381.20801182
Bhat VS, Hester SD, Nesnow S, Eastmond DA. 2013. Concordance of transcriptional and apical benchmark dose levels for conazole-induced liver effects in mice. Toxicol Sci 136:205–215.23970803
Bianchi E, Costa E, Yan ZJ, Murphy L, Howell J, Anderson D, . 2021. A rat subchronic study transcriptional point of departure estimates a carcinogenicity study apical point of departure. Food Chem Toxicol 147:111869.33217531
Black MB, Parks BB, Pluta L, Chu TM, Allen BC, Wolfinger RD, . 2014. Comparison of microarrays and RNA-seq for gene expression analyses of dose-response experiments. Toxicol Sci 137:385–403.24194394
Bushel PR, Paules RS, Auerbach SS. 2018. A Comparison of the TempO-Seq S1500+ Platform to RNA-Seq and Microarray Using Rat Liver Mode of Action Samples. Front Genet 9:485.30420870
Cannizzo MD, Wood CE, Hester SD, Wehmas LC. 2022. Case study: Targeted RNA-sequencing of aged formalin-fixed paraffin-embedded samples for understanding chemical mode of action. Toxicol Rep 9:883–894.36518475
Catlin NR, Collins BJ, Auerbach SS, Ferguson SS, Harnly JM, Gennings C, . 2018. How similar is similar enough? A sufficient similarity case study with Ginkgo biloba extract. Food Chem Toxicol 118:328–339.29752982
Chepelev NL, Moffat ID, Labib S, Bourdon-Lacombe J, Kuo B, Buick JK, . 2015. Integrating toxicogenomics into human health risk assessment: lessons learned from the benzo[a]pyrene case study. Crit Rev Toxicol 45:44–52.25605027
Chepelev NL, Gagné R, Maynor T, Kuo B, Hobbs CA, Recio L, . 2017. Transcriptional profiling of male F344 rats suggests the involvement of calcium signaling in the mode of action of acrylamide-induced thyroid cancer. Food Chem Toxicol 107:186–200.28606764
Chepelev NL, Gagné R, Maynor T, Kuo B, Hobbs CA, Recio L, . 2018. Transcriptional profiling of male CD-1 mouse lungs and Harderian glands supports the involvement of calcium signaling in acrylamide-induced tumors. Regul Toxicol Pharmacol 95:75–90.29475067
Clewell HJ, Thomas RS, Kenyon EM, Hughes MF, Adair BM, Gentry PR, . 2011. Concentration- and time-dependent genomic changes in the mouse urinary bladder following exposure to arsenate in drinking water for up to 12 weeks. Toxicol Sci 123:421–432.21795629
Clewell HJ, Efremenko A, Campbell JL, Dodd DE, Thomas RS. 2014. Transcriptional responses in the rat nasal epithelium following subchronic inhalation of naphthalene vapor. Toxicol Appl Pharmacol 280:78–85.24976557
Danforth C, Chiu WA, Rusyn I, Schultz K, Bolden A, Kwiatkowski C, . 2020. An integrative method for identification and prioritization of constituents of concern in produced water from onshore oil and gas extraction. Environ Int 134:105280.31704566
Dent MP. 2007. Strengths and limitations of using repeat-dose toxicity studies to predict effects on fertility. Regul Toxicol Pharmacol 48:241–258.17512650
Dong H, Gill S, Curran IH, Williams A, Kuo B, Wade MG, . 2016. Toxicogenomic assessment of liver responses following subchronic exposure to furan in Fischer F344 rats. Arch Toxicol 90:1351–1367.26194646
Dunnick JK, Shockley KR, Morgan DL, Brix A, Travlos GS, Gerrish K, . 2017. Hepatic transcriptomic alterations for N,N-dimethyl-p-toluidine (DMPT) and p-toluidine after 5-day exposure in rats. Arch Toxicol 91:1685–1696.27638505
EEA. 2018. Chemicals for a Sustainable Future – Report of the EEA Scientific Committee Seminar. 978-92-9213-936-0. Luxembourg:European Environment Agency.
EPA. 2004a. Acetochlor Report of the Cancer Assessment Review Committee (CARC). Washington, D.C.
EPA. 2004b. Potential Implications of Genomics for Regulatory and Risk Assessment Applications at EPA. EPA 100/B-04/002. Washington, DC.
EPA. 2007. Interim Guidance for Microarray-Based Assays: Data Submission, Quality, Analysis, Data Management, and Training Considerations External Review Draft. Washington, DC.
EPA. 2009. An Approach To Using Toxicogenomic Data in U.S. EPA Human Health Risk Assessments: A Dibutyl Phthalate Case Study. EPA/600/R-09/028F. Washington, DC:U.S. Environmental Protection Agency.
EPA. 2012. Benchmark Dose Technical Guidance. EPA/100/R-12/001. Washington, DC:U.S. Environmental Protection Agency.
EPA. 2021. New Approach Methods Work Plan. EPA/600/X-21/209. Washington, DC:U.S. Environmental Protection Agency.
EPA. 2022. ORD Staff Handook for Developing IRIS Assessments. EPA 600/R-22/268. Research Triangle Park, NC:U.S. Environmental Protection Agency.
EPA. 2024a. Value of Information Case Study on the Human Health and Economic Trade-offs Associated with the Timeliness, Uncertainty, and Costs of the Draft EPA Transcriptomic Assessment Product (ETAP). EPA/600/X-23/082. Research Triangle Park, NC:U.S. Environmental Protection Agency.
EPA. 2024b. Standard Methods for Development of EPA Transcriptomic Assessment Products (ETAPs). EPA/600/X-23/083. Research Triangle Park, NC:U.S. Environmental Protection Agency.
Farmahin R, Williams A, Kuo B, Chepelev NL, Thomas RS, Barton-Maclaren TS, . 2017. Recommended approaches in the application of toxicogenomics to derive points of departure for chemical risk assessment. Arch Toxicol 91:2045–2065.27928627
Foox J, Tighe SW, Nicolet CM, Zook JM, Byrska-Bishop M, Clarke WE, . 2021. Performance assessment of DNA sequencing platforms in the ABRF Next-Generation Sequencing Study. Nat Biotechnol 39:1129–1140.34504351
Fowler T, Sen R, Roy AL. 2011. Regulation of primary response genes. Mol Cell 44:348–360.22055182
Gelbke HP, Hofmann A, Owens JW, Freyberger A. 2007. The enhancement of the subacute repeat dose toxicity test OECD TG 407 for the detection of endocrine active chemicals: comparison with toxicity tests of longer duration. Arch Toxicol 81:227–250.17047927
Geter DR, Bhat VS, Gollapudi BB, Sura R, Hester SD. 2014. Dose-response modeling of early molecular and cellular key events in the CAR-mediated hepatocarcinogenesis pathway. Toxicol Sci 138:425–445.24449422
Gwinn WM, Auerbach SS, Parham F, Stout MD, Waidyanatha S, Mutlu E, . 2020. Evaluation of 5-day In Vivo Rat Liver and Kidney With High-throughput Transcriptomics for Estimating Benchmark Doses of Apical Outcomes. Toxicol Sci 176:343–354.32492150
Hagiwara S, Paoli GM, Price PS, Gwinn MR, Guiseppi-Elie A, Farrell PJ, . 2022. A value of information framework for assessing the trade-offs associated with uncertainty, duration, and cost of chemical toxicity testing. Risk Anal 43:498–515.35460101
Harrill JA, Everett LJ, Haggard DE, Sheffield T, Bundy JL, Willis CM, . 2021a. High-Throughput Transcriptomics Platform for Screening Environmental Chemicals. Toxicol Sci 181:68–89.33538836
Harrill JA, Viant MR, Yauk CL, Sachana M, Gant TW, Auerbach SS, . 2021b. Progress towards an OECD reporting framework for transcriptomics and metabolomics in regulatory toxicology. Regul Toxicol Pharmacol 125:105020.34333066
Hester S, Eastmond DA, Bhat VS. 2015. Developing toxicogenomics as a research tool by applying benchmark dose-response modelling to inform chemical mode of action and tumorigenic potency. Int J of Biotechnol 14:28–46.
Hester SD, Bhat V, Chorley BN, Carswell G, Jones W, Wehmas LC, . 2016. Editor’s Highlight: Dose-Response Analysis of RNA-Seq Profiles in Archival Formalin-Fixed Paraffin-Embedded Samples. Toxicol Sci 154:202–213.27562560
Isaacs KK, Wall JT, Williams AR, Hobbie KA, Sobus JR, Ulrich E, . 2022. A harmonized chemical monitoring database for support of exposure assessments. Sci Data 9:314.35710792
Jackson AF, Williams A, Recio L, Waters MD, Lambert IB, Yauk CL. 2014. Case study on the utility of hepatic global gene expression profiling in the risk assessment of the carcinogen furan. Toxicol Appl Pharmacol 274:63–77.24183702
Janer G, Hakkert BC, Piersma AH, Vermeire T, Slob W. 2007. A retrospective analysis of the added value of the rat two-generation reproductive toxicity study versus the rat subchronic toxicity study. Reprod Toxicol 24:103–113.17600672
Johnson KJ, Auerbach SS, Costa E. 2020. A Rat Liver Transcriptomic Point of Departure Predicts a Prospective Liver or Non-liver Apical Point of Departure. Toxicol Sci 176:86–102.32384157
Johnson KJ, Auerbach SS, Stevens T, Barton-Maclaren TS, Costa E, Currie RA, . 2022. A Transformative Vision for an Omics-Based Regulatory Chemical Testing Paradigm. Toxicol Sci 190:127–132.36165699
Kim D, Langmead B, Salzberg SL. 2015. HISAT: a fast spliced aligner with low memory requirements. Nat Methods 12:357–360.25751142
Kim D, Paggi JM, Park C, Bennett C, Salzberg SL. 2019. Graph-based genome alignment and genotyping with HISAT2 and HISAT-genotype. Nat Biotechnol 37:907–915.31375807
Krewski D, Andersen ME, Tyshenko MG, Krishnan K, Hartung T, Boekelheide K, . 2020. Toxicity testing in the 21st century: progress in the past decade and future perspectives. Arch Toxicol 94:1–58.31848664
Labib S, Williams A, Guo CH, Leingartner K, Arlt VM, Schmeiser HH, . 2016. Comparative transcriptomic analyses to scrutinize the assumption that genotoxic PAHs exert effects via a common mode of action. Arch Toxicol 90:2461–2480.26377693
Labib S, Williams A, Kuo B, Yauk CL, White PA, Halappanavar S. 2017. A framework for the use of single-chemical transcriptomics data in predicting the hazards associated with complex mixtures of polycyclic aromatic hydrocarbons. Arch Toxicol 91:2599–2616.27858113
Lake AD, Wood CE, Bhat VS, Chorley BN, Carswell GK, Sey YM, . 2016. Dose and Effect Thresholds for Early Key Events in a PPARα-Mediated Mode of Action. Toxicol Sci 149:312–325.26519955
LaRocca J, Costa E, Sriram S, Hannas BR, Johnson KJ. 2020. Short-term toxicogenomics as an alternative approach to chronic in vivo studies for derivation of points of departure: A case study in the rat with a triazole fungicide. Regul Toxicol Pharmacol 113:104655.32268158
Li D, Kusko R, Ning B, Tong W, Johann DJ, Jr., Xu J. 2021. FDA-led consortium studies advance quality control of targeted next generation sequencing assays for precision oncology. Precis Cancer Med 4.
Li H, Handsaker B, Wysoker A, Fennell T, Ruan J, Homer N, . 2009. The Sequence Alignment/Map format and SAMtools. Bioinformatics 25:2078–2079.19505943
Li S, Tighe SW, Nicolet CM, Grove D, Levy S, Farmerie W, . 2014. Multi-platform assessment of transcriptome profiling using RNA-seq in the ABRF next-generation sequencing study. Nat Biotechnol 32:915–925.25150835
Lobenhofer EK, Cui X, Bennett L, Cable PL, Merrick BA, Churchill GA, . 2004. Exploration of low-dose estrogen effects: identification of No Observed Transcriptional Effect Level (NOTEL). Toxicol Pathol 32:482–492.15223774
MAQC. 2006. The MicroArray Quality Control (MAQC) project shows inter- and intraplatform reproducibility of gene expression measurements. Nat Biotechnol 24:1151–1161.16964229
Mav D, Shah RR, Howard BE, Auerbach SS, Bushel PR, Collins JB, . 2018. A hybrid gene selection approach to create the S1500+ targeted gene sets for use in high-throughput transcriptomics. PLoS One 13:e0191105.29462216
Mercer TR, Xu J, Mason CE, Tong W, on behalf of the MSC. 2021. The Sequencing Quality Control 2 study: establishing community standards for sequencing in precision medicine. Genome Biol 22:306.34749795
Moffat I, Chepelev N, Labib S, Bourdon-Lacombe J, Kuo B, Buick JK, . 2015. Comparison of toxicogenomics and traditional approaches to inform mode of action and points of departure in human health risk assessment of benzo[a]pyrene in drinking water. Crit Rev Toxicol 45:1–43.
NASEM. 2007. Toxicity Testing in the 21st Century: A Vision and a Strategy. Washington, D.C.:National Academies of Sciences, Engineering, and Medicine.
NASEM. 2009. Science and Decisions: Advancing Risk Assessment. Washington, DC:National Academies of Sciences, Engineering, and Medicine.
National Toxicology P. 2018. NTP Research Reports. In: NTP Research Report on In Vivo Repeat Dose Biological Potency Study of Triphenyl Phosphate (CAS No 115-86-6) in Male Sprague Dawley Rats (Hsd: Sprague Dawley SD) (Gavage Studies): Research Report 8. Durham (NC):National Toxicology Program.
NIEHS. 2022a. NIEHS Report on the In Vivo Repeat Dose Biological Potency Study of Tricresyl Phosphate (CASRN 1330-78-5) in Male Sprague Dawley (Hsd:Sprague Dawley® SD®) Rats (Gavage Studies). NIEHS Report 06. Research Triangle Park, NC:U.S. Department of Health and Human Services.
NIEHS. 2022b. NIEHS Report on the In Vivo Repeat Dose Biological Potency Study of 2-Ethylhexyl Diphenyl Phosphate (CASRN 1241-94-7) in Male Sprague Dawley (Hsd:Sprague Dawley® SD®) Rats (Gavage Studies). NIEHS Report 02. Research Triangle Park, NC.
NIEHS. 2022c. NIEHS Report on In Vivo Repeat Dose Biological Potency Study of tert-Butylphenyl Diphenyl Phosphate (CASRN 56803-37-3) in Male Sprague Dawley (Hsd:Sprague Dawley® SD®) Rats(Gavage Studies) NIEHS Report 03 Research Triangle Park, NC.
NIEHS. 2022d. NIEHS Report on the In Vivo Repeat Dose Biological Potency Study of Isodecyl Diphenyl Phosphate (CASRN 29761-21-5) in Male Sprague Dawley (Hsd:Sprague Dawley® SD®) Rats (Gavage Studies). NIEHS Report 04. Research Triangle Park, NC.
NTP. 2011. Toxicology and Carcinogenesis Studies of Milk Thistle Extract (CASRN 84604-20-6) in F344/N Rats and B6C3F1 Mice (Feed studies). TR-565. Research Triangle Park, NC:National Toxicology Program.
NTP. 2014. Toxicology Studies of Tetrabromobisphenol A in F344/NTac Rats and B6C3F1/N Mice and Toxicology and Carcinogenesis Studies of Tetrabromobisphenol A in Wistar Han [Crl:WI(Han)] Rats and B6C3F1/N Mice (Gavage Studies). TR-587. Research Triangle Park, NC:National Toxicology Program.
NTP. 2018. NTP Research Report on National Toxicology Program Approach to Genomic Dose-Response Modeling. NTP-RR-5. Research Triangle Park, NC:National Toxicology Program, U.S. Department of Health and Human Services.
NTP. 2021. NTP Technical Report on the Toxicology and Carcinogenesis Studies of Di(2-ethylhexyl) Phthalate (CASRN 117-81-7) Administered in Feed to Sprague Dawley (HSD:Sprague Dawley SD) Rats. NTP TR 601. Research Triangle Park, NC:National Toxicology Program.
NTP. 2022. Chemical Effects in Biological Systems (CEBS). Research Triangle Park, USA:National Toxicology Program.
OE. 2019. The Global Chemical Industry: Catalyzing Growth and Addressing Our World’s Sustainability Challenges. Washington, DC:Oxford Economics.
OECD. 2018. Toward a New Comprehensive Global Database of Per- and polyfluoroalkyl substances (PFASs): Summary Report on Updating the OeCD 2007 List of Per- and Polyfluoroalkyl Substances (PFASs). ENV/JM/MONO(2018)7.Organization for Economic Cooperation and Development.
Owens W, Koeter HB. 2003. The OECD program to validate the rat uterotrophic bioassay: an overview. Environ Health Perspect 111:1527–1529.12948895
Owens W, Gray LE, Zeiger E, Walker M, Yamasaki K, Ashby J, . 2007. The OECD program to validate the rat Hershberger bioassay to screen compounds for in vivo androgen and antiandrogen responses: phase 2 dose-response studies. Environ Health Perspect 115:671–678.17520051
Pham LL, Watford S, Pradeep P, Martin MT, Thomas R, Judson R, . 2020. Variability in in vivo studies: Defining the upper limit of performance for predictions of systemic effect levels. Comput Toxicol 15:1–100126.33426408
Phillips JR, Svoboda DL, Tandon A, Patel S, Sedykh A, Mav D, . 2019. BMDExpress 2: enhanced transcriptomic dose-response analysis workflow. Bioinformatics 35:1780–1782.30329029
Recio L, Friedman M, Marroni D, Maynor T, Chepelev NL. 2017. Impact of Acrylamide on Calcium Signaling and Cytoskeletal Filaments in Testes From F344 Rat. Int J Toxicol 36:124–132.28403741
Rowlands JC, Budinsky R, Gollapudi B, Black MB, Wolfinger RD, Cukovic D, . 2013. A genomics-based analysis of relative potencies of dioxin-like compounds in primary rat hepatocytes. Toxicol Sci 136:595–604.24046277
SEQC. 2014. A comprehensive assessment of RNA-seq accuracy, reproducibility and information content by the Sequencing Quality Control Consortium. Nat Biotechnol 32:903–914.25150838
SEQC/MAQC-III. 2014. A comprehensive assessment of RNA-seq accuracy, reproducibility and information content by the Sequencing Quality Control Consortium. Nat Biotechnol 32:903–914.25150838
Shockley KR, Cora MC, Malarkey DE, Jackson-Humbles D, Vallant M, Collins BJ, . 2020. Comparative toxicity and liver transcriptomics of legacy and emerging brominated flame retardants following 5-day exposure in the rat. Toxicol Lett 332:222–234.32679240
Thomas RS, Allen BC, Nong A, Yang L, Bermudez E, Clewell HJ, 3rd, . 2007. A method to integrate benchmark dose estimates with genomic data to assess the functional effects of chemical exposure. Toxicol Sci 98:240–248.17449896
Thomas RS, Clewell HJ, 3rd, Allen BC, Wesselkamper SC, Wang NC, Lambert JC, . 2011. Application of transcriptional benchmark dose values in quantitative cancer and noncancer risk assessment. Toxicol Sci 120:194–205.21097997
Thomas RS, Clewell HJ, 3rd, Allen BC, Yang L, Healy E, Andersen ME. 2012. Integrating pathway-based transcriptomic data into quantitative chemical risk assessment: a five chemical case study. Mutat Res 746:135–143.22305970
Thomas RS, Himmelstein MW, Clewell HJ, 3rd, Yang Y, Healy E, Black MB, . 2013a. Cross-species transcriptomic analysis of mouse and rat lung exposed to chloroprene. Toxicol Sci 131:629–640.23125180
Thomas RS, Wesselkamper SC, Wang NC, Zhao QJ, Petersen DD, Lambert JC, . 2013b. Temporal concordance between apical and transcriptional points of departure for chemical risk assessment. Toxicol Sci 134:180–194.23596260
Tullai JW, Schaffer ME, Mullenbrock S, Sholder G, Kasif S, Cooper GM. 2007. Immediate-early and delayed primary response genes are distinct in function and genomic architecture. J Biol Chem 282:23981–23995.17575275
Wang Z, Walker GW, Muir DCG, Nagatani-Yoshida K. 2020. Toward a Global Understanding of Chemical Pollution: A First Comprehensive Analysis of National and Regional Chemical Inventories. Environ Sci Technol 54:2575–2584.31968937
Yang L, Allen BC, Thomas RS. 2007. BMDExpress: a software tool for the benchmark dose analyses of genomic data. BMC Genomics 8:387.17961223
Yeakley JM, Shepard PJ, Goyena DE, VanSteenhouse HC, McComb JD, Seligmann BE. 2017. A trichostatin A expression signature identified by TempO-Seq targeted whole transcriptome profiling. PLoS One 12:e0178302.28542535
Zhou T, Chou J, Watkins PB, Kaufmann WK. 2009. Toxicogenomics: transcription profiling for toxicology assessment. Exs 99:325–366.19157067
Zhou YH, Cichocki JA, Soldatow VY, Scholl EH, Gallins PJ, Jima D, . 2017. Editor’s Highlight: Comparative Dose-Response Analysis of Liver and Kidney Transcriptomic Effects of Trichloroethylene and Tetrachloroethylene in B6C3F1 Mouse. Toxicol Sci 160:95–110.28973375