# AUTHORS | CONTRIBUTORS

EPA Office of Research and Development (ORD) Authors
Dan Chang | EPA/ORD/CCTE
John Cowden | EPA/ORD/CCTE
Sarah Davidson-Fritz | EPA/ORD/CCTE
Jeffry Dean | EPA/ORD/CPHEA
Mike Devito | EPA/ORD/CCTE
Logan Everett | EPA/ORD/CCTE
Alison Harrill | EPA/ORD/CCTE
Susan Hester | EPA/ORD/CCTE (retired)
Michael Hughes | EPA/ORD/CCTE
Jason Lambert | EPA/ORD/CCTE
Lucina Lizarraga | EPA/ORD/CPHEA
Roman Mezencev | EPA/ORD/CPHEA
Grace Patlewicz | EPA/ORD/CCTE
Kristina Thayer | EPA/ORD/CPHEA
Russell Thomas | EPA/ORD/CCTE
Kelsey Vitense | EPA/ORD/CCTE
Leah Wehmas | EPA/ORD/CCTE
NIEHS Division of Translational Toxicology (DTT) Authors
Scott Auerbach | NTP/DTT/NIEHS/NIH
Warren Casey | NTP/DTT/NIEHS/NIH
EPA ORD Executive Direction
Russell Thomas | CCTE Center Director
Reeder Sams | CCTE Deputy Center Director
Jason Lambert | CCTE Senior Science Advisor
Alison Harrill | CCTE Associate Director
Mike Devito | CCTE/CCED Division Director
Sid Hunter | CCTE/BCTD Division Director
Michael Hughes | CCTE/CCED/ETTB Branch Chief
Dan Chang | CCTE/CCED/CCCB Branch Chief
John Cowden | CCTE/BCTD/CTBB Branch Chief
Wayne Cascio | CPHEA Center Director
Kay Holt | CPHEA Deputy Center Director
Samantha Jones | CPHEA Associate Director
Kris Thayer | CPHEA/CPAD Division Director
Ravi Subramaniam | CPHEA/CPAD/TEABD Branch Chief
Glenn Rice | CPHEA/CPAD/TEABC Branch Chief
EPA and DTT Contributors and Reviewers
John Bucher | NTP/DTT/NIEHS/NIH
Timothy Buckley | EPA/ORD/CCTE
Peter Egeghy | EPA/ORD/CCTE
Katie Paul-Friedman | EPA/ORD/CCTE
Joshua Harrill | EPA/ORD/CCTE
Sid Hunter | EPA/ORD/CCTE
Kristin Isaacs | EPA/ORD/CCTE
Richard Judson | EPA/ORD/CCTE
Jonathan Kaiser | EPA/ORD/CPHEA
Scott Masten | NTP/DTT/NIEHS/NIH
Fred Parham | NTP/DTT/NIEHS/NIH
Grace Patlewicz | EPA/ORD/CCTE
Dan Petersen | EPA/ORD/CPHEA
Allison Phillips | EPA/ORD/CPHEA
Jon Sobus | EPA/ORD/CCTE
Daniel Villeneuve | EPA/ORD/CCTE
Paul White | EPA/ORD/CPHEA
Antony Williams | EPA/ORD/CCTE
George Woodall | EPA/ORD/CPHEA
Jay Zhao | EPA/ORD/CPHEA