# 5 SUMMARY AND CONCLUSIONS

Regulatory agencies, such as EPA, face substantial challenges evaluating and managing the human health risks of the thousands of chemicals and mixtures on their respective inventories. Relatively few of the chemicals have traditional toxicity data and fewer have human health assessments that could be used to inform regulatory decisions. Technologies, such as transcriptomics, have potential to more rapidly evaluate potential human health effects and play a role in filling the data gaps in toxicity testing and human health assessment. In recognition of the potential of transcriptomics, the EPA issued a series of guidance, white papers, and reports between 2004 – 2007 that identified areas of application and barriers to implementation. The key barriers included a technical framework for genomic data analysis, criteria for acceptance of transcriptomics data, and consistency in methods for interpreting and analyzing transcriptomics data. Since that time, the technology and analysis methods for characterizing transcriptomic responses have matured and many of the barriers have been addressed through additional research and initiatives such as the MAQC/SEQC studies on reproducibility (MAQC 2006; SEQC 2014), the NTP consensus report on transcriptomic dose response modeling (NTP 2018), and OECD reporting template (Harrill et al. 2021b).

To evaluate the state of the science for using transcriptomics in quantitative human health assessment, a literature review was conducted comparing the concordance between transcriptomic PODs from short-term in vivo studies in rodents with apical PODs from traditional in vivo toxicity studies. The literature survey identified over 140 chemicals with diverse properties tested in 33 independent studies with varying experimental designs. The results of the literature survey demonstrated that transcriptomic BMD and BMDL values, when integrated at a gene set level, were consistently concordant with BMD and BMDL values for apical responses in traditional subchronic and chronic rodent toxicity studies. The transcriptomic and apical dose concordance was robust across different exposure durations, exposure routes, species, sex, target tissues, physicochemical properties, toxicokinetic half-lives, and technology platforms. For the 40 chemicals with reported chronic rodent bioassays results, the Pearson’s correlation coefficient was 0.820 with a log_10_ RMSD of 0.593 (log_10_ mg/kg-day) and a median absolute ratio of 2.4 ± 1.0 (MAD). The RMSD value is similar to the range of inter-study standard deviation estimates for the LOAELs for systemic toxicity in repeated dose studies, approximated as residual RMSE in log10-mg/kg-day units [0.45-0.56; (Pham et al. 2020)]. The results suggest that the error associated with the concordance between the transcriptomic BMD values versus non-cancer and cancer apical BMD values is approximately equivalent to the inter-study variability in the repeated dose toxicity study itself.

In order to apply transcriptomics to human health assessment, a defined study design and data analysis process was evaluated to derive transcriptomic PODs based on recommendations in the peer-reviewed National Toxicology Program Approach to Genomic Dose Response Modeling report (NTP 2018). The study design utilizes a 5-day, repeated dose in vivo study in male and female rats with an extended dose response series. The transcriptomic dose response modeling follows a stepwise process that utilizes BMD modeling approaches that are commonly employed in chemical risk assessment. A transcriptomic dose response modeling process was identified that resulted in a Pearson correlation coefficient and log_10_ RMSD for the transcriptomic and chronic apical BMD values of 0.910 and 0.567, respectively. The median absolute ratio of the transcriptomic BMD and chronic apical BMD values was 3.2 ± 1.9 (MAD). The inter-study transcriptomic BMD standard deviation for a subset of chemicals that were independently replicated was 0.242 (log_10_ mg/kg-day). The estimated family-wise error rate for identifying a gene set level BMD was 0.006. A statistical analysis demonstrated that the error associated with the concordance between the transcriptomic BMD values versus non-cancer and cancer apical BMD values was approximately equivalent to the combined inter-study variability associated with the 5-day transcriptomic study and the two-year rodent bioassay. The performance of the method in approximating an apical POD from two-year toxicity studies, the inter-study variability, and low family-wise error rate support the application of the defined study design and data analysis process to quantitative human health assessment.

There are caveats and limitations in the application of transcriptomic dose response to human health assessment and the analysis undertaken in this report. First, the use of gene sets for estimating the POD does not provide a direct measurement or link to a specific adversity. Rather, the POD must be interpreted as the dose at which there were no coordinated transcriptional changes that would indicate a potential toxicity of concern. The coordinated transcriptional changes used to identify the POD also do not necessarily discriminate between specific hazards, nor are they used to infer a mechanism or mode of action. Additional time points and analysis would be required to build a weight of evidence for a mode of action. Second, the coordinated transcriptional changes associated with the POD may be an adaptive response to chemical treatment rather than biological changes leading to an adverse endpoint. In the study by Gwinn and colleagues, two botanicals, ginseng and milk thistle extract, and tetrabromobisphenol A were not labeled as having either non-cancer or cancer-related lesions in male rats in the chronic bioassay, but the treatments did induce transcriptional changes and transcriptomic BMD values in the liver and kidney (Gwinn et al. 2020). However, in the original NTP reports, tetrabromobisphenol A was reported to have a reduction in body weight at the middle and high dose levels (NTP 2014) and milk thistle extract showed a reduction in biliary hyperplasia and mixed cell infiltration at the high dose (NTP 2011). While the histopathological changes following treatment with milk thistle extract may not be considered adverse in a traditional assessment context, apical changes were present that may have contributed to the transcriptional responses. Third, the use of the 5-day, repeat dose study with adult animals may not be predictive or protective of other health domains, such as developmental toxicity, reproductive toxicity, immunotoxicity, and neurotoxicity. Although this is also true of the traditional studies designed to assess systemic toxicity, a previous retrospective analysis demonstrated that apical data from subchronic toxicity studies can predict effects on fertility (Dent 2007), while a separate retrospective analysis showed less than a two-fold difference in NOAEL values between rat subchronic studies and two-generation reproductive and developmental studies (Janer et al. 2007). Given the concordance between transcriptomic PODs from short-term studies and apical PODs from subchronic and chronic toxicity studies, these two retrospective analyses suggest that transcriptomic PODs may also be protective of apical PODs for other toxic effects, but further studies would be necessary to more confidently establish the degree of protection. Finally, the 14 chemicals and associated inter-study replicates used to refine the transcriptomic dose response methods may not be a random, representative sample of the chemicals that may be evaluated by ETAP in the future. Given the selection and relatively limited number of chemicals, the results may provide an overly optimistic assessment of the performance of the method when applied to new chemicals. However, the concordance associated with the 14 chemicals was similar to that identified for the 40 chemicals from the literature survey with chronic rodent BMD results, which suggests that the findings are a reasonable estimate. In addition, the number of chemicals used to refine the transcriptomic dose response methods and assess performance is similar to that used in the validation of multiple guideline assays and enhancements (Gelbke et al. 2007; Owens and Koeter 2003; Owens et al. 2007).

The overall conclusions from the literature survey, evaluation of the transcriptomic dose response analysis methods, and the statistical comparison of the concordance with inter-study variances support the use of transcriptomic PODs from 5-day, repeated dose in vivo rodent studies in quantitative human health assessments. The historical barriers that thus far limited application of transcriptomics in regulatory decision-making have mostly been addressed and the methods have undergone extensive peer-review in the individual publications and NTP report. While certain caveats and limitations remain, EPA is proposing to apply these methods in a standardized human health assessment framework to address the substantial data gaps that exist among chemicals that lack traditional toxicity testing data (EPA 2024b).

28 The chronic two-year bioassay results for BMD modeling were obtained from the NTP histopathological tables posted for peer review: https://ntp.niehs.nih.gov/go/TS-m20263

29 The latest version of Abstract Sifter can be downloaded from the EPA Computational Toxicology data download site at: https://www.epa.gov/chemical-research/downloadable-computational-toxicology-data

30 For explanation of how the ‘Like articles’ are selected through Pubmed see: https://pubmed.ncbi.nlm.nih.gov/help/#computation-of-similar-articles