# 3 REVIEW OF TRANSCRIPTOMIC DOSE RESPONSE LITERATURE

The literature summary provides expert-selected and reviewed studies that are relevant to application of transcriptomics in quantitative human health assessment in the specific context of the ETAP. The summary includes a brief history of transcriptomics at EPA, evaluation of the reproducibility of the technology, and the transcriptomic dose response literature as it pertains to the concordance of transcriptomic BMD(L)^14^ with apical endpoints in standard toxicity studies. The literature search strategy is provided in Section 6.3 of the Appendix.

## 3.1 EPA HISTORY, POLICIES, AND USE OF TRANSCRIPTOMICS

The EPA has a longstanding commitment toward utilizing emerging and novel technologies to enhance testing paradigms and to improve the utility and predictability of risk assessment methods. Transcriptomic data are particularly attractive in this context because changes in gene transcript (mRNA) expression are frequently observed to precede or coincide with clinical or phenotypically observable changes (i.e., apical effects), thereby providing a sensitive measurement of chemical-induced bioactivity (Hester et al. 2015; Lobenhofer et al. 2004; Thomas et al. 2011). Toward adoption of transcriptomics data, the Agency issued an interim policy on genomics in 2002 that advocated using transcriptomics data to enhance assessments and priority setting on a case-by-case basis within weight of evidence-based approaches (EPA 2004b). This Interim Policy was followed by a white paper issued by a task force of cross-Agency experts to investigate potential implications of transcriptomics on EPA programs and policies. While the Interim Policy limited consideration of transcriptomics data only in concert with traditional toxicology endpoints, the 2004 white paper on Potential Implications of Genomics for Regulatory and Risk Assessment Application at the EPA expanded the recommendations to include four areas of likely impact for genomics data within the Agency and for external submissions to the Agency. The recommended applications of transcriptomics data included prioritization of contaminants and contaminated sites and risk assessment (EPA 2004b). Key gaps that were identified as barriers to implementation at the time included a lack of adequate technical infrastructure and training of qualified personnel, as well as a need to develop a technical framework for genomic data analysis and standardization criteria for acceptance of transcriptomics data. In the same year (2004), the EPA’s Office of Pesticides Programs utilized transcriptomics data in a mode of action, weight of evidence cancer risk assessment of acetochlor (EPA 2004a). Supporting the mode of action assessment were time course-derived transcriptomic data of the rat olfactory mucosa at a single dose; early gene expression changes were consistent with oxidative damage to DNA followed by cell proliferation, and late gene expression changes were consistent with tumorigenic progression.

In 2007, the EPA released interim guidance for microarray data submissions, quality, and analysis – Interim Guidance for Microarray-Based Assays; Data Submission, Quality, Analysis, Management and Training Considerations (EPA 2007). The guidance was developed by a team of experts from multiple EPA programs and regional offices who were convened at the request of the EPA’s Office of the Science Advisor (Hester et al. 2015). The interim guidance provided recommendations on performance approaches for quality assessment parameters, data analysis approaches, Agency data submissions, and data management practices. In addition, the guidance included a draft Genomics Data Evaluation Records template and recommendations for development of training modules and materials for risk assessors, cross-Agency collaboration, and case study applications.

Research into application of transcriptomic data to risk assessment continued to expand in subsequent years. In 2009, EPA released a case study for application of transcriptomic data to human health risk assessment of dibutyl phthalate (EPA 2009). The case study outlined a pragmatic and flexible approach to accommodate different health and risk assessment practices and focused primarily on informing mode of action as part of a weight of evidence. At the time, the authors noted limitations that resonated from prior guidance documents and case studies, specifically that there was a need for consistency in methods for interpreting and analyzing transcriptomics data.

For application to quantitative human health risk assessment, standardized methods and software applications have since been developed for analyzing transcriptomic changes as a function of dose through calculating BMD values at the gene, pathway, biological process, or molecular function level (Farmahin et al. 2017; NTP 2018; Phillips et al. 2019; Thomas et al. 2007; Yang et al. 2007). BMDExpress has become a widely adopted graphical user interface-based software package that facilitates analysis of transcriptomic dose response data (Phillips et al. 2019; Yang et al. 2007). BMDExpress employs validated continuous parametric models deployed in the EPA’s BMDS software^15^. In the BMDExpress workflow, curve fits are computed for each gene transcript, followed by functional classification analysis that assigns transcriptomic features into pre-defined gene sets^16^ [e.g., Gene Ontology (GO) classes] and determines gene set level potency estimates for each of the populated gene sets [i.e., a gene set BMD(L)]. The individual probe/gene-level modeling process is consistent with recommendations by the EPA for benchmark dose modeling in toxicological assessments (EPA 2012). The BMDExpress software release (version 2) is in use by EPA and partner agencies, including Health Canada and the US National Institutes of Health (NIH), who developed the software along with the contractor Sciome (Phillips et al. 2019). Methods and assumptions underlying use of BMDExpress for analysis of transcriptomic dose response data were reviewed by an NIH-assembled panel of external experts with the resulting method published in 2018 (NTP 2018).

In parallel, standardized reporting templates for transcriptomics data have been developed in collaboration with international partners, addressing the remaining key gap identified in prior Agency guidances and case studies. In 2021, EPA scientists co-led an OECD team that created the first formal reporting framework of the processing and analysis of transcriptomic data for regulatory toxicology use [i.e., the OECD Omics Reporting Framework^17^ (Harrill et al. 2021b)]. Similarly, the NIH’s Division of Translational Toxicology (DTT; formerly called the Division of the National Toxicology Program) has established standard methods and a reporting framework for their internal transcriptomic dose response studies and has used this reporting standard to disseminate data on several organophosphate flame retardant chemicals (NIEHS 2022b, c, d). Taken together, the past decade has yielded significant advances in the standardization of methods, analysis frameworks, and reporting standards, as well as training and capacity building, to address prior Agency-identified critical gaps and to support the use of transcriptomics in regulatory science at the EPA.

## 3.2 REPRODUCIBILITY OF TRANSCRIPTOMIC DATA

Confidence in the application of transcriptomics data is bolstered by the work of international consortia who have completed projects investigating inter- and intra-platform reproducibility of gene expression measurements by standard methods, including microarrays and ribonucleic acid sequencing (RNA-seq) technologies. Reliability of the methods used to measure changes in gene expression is one of the main principles identified as necessary for application of transcriptomic data in quantitative human health assessments (Johnson et al. 2022). The MicroArray Quality Consortium (MAQC; led by the US Food and Drug Administration) conducted cross-site, cross-platform studies to evaluate performance through the titration of two reference RNA samples (MAQC 2006). The Consortium demonstrated strong inter- and intra-platform reproducibility of gene expression measurements by microarrays and high correlation in quantitative expression between traditional reverse transcription-polymerase chain reaction (RT-PCR) assays and microarray results. The MAQC studies demonstrated that the combination of fold-change ranking and a non-stringent p-value cutoff led to increased consistency in differential gene expression results across laboratories. These and subsequent studies led to the MAQC launching the Sequencing Quality Control (SEQC) project to evaluate emerging next-generation sequencing (NGS) technologies. The first SEQC projects established best-practices for RNA-seq methods of measuring gene expression, compared RNA-seq performance to microarrays (SEQC/MAQC-III 2014), characterized inter-platform reproducibility of RNA-seq protocols and technologies (Li et al. 2014), and evaluated the bioinformatic tools increasingly required to analyze large and complex RNA-seq datasets (Li et al. 2014). Similar to the microarray reproducibility studies, the SEQC cross-site, cross-platform study demonstrated high consistency in RNA-seq results with intra- and inter-platform Spearman rank concordance values at r > 0.86 and r > 0.83, respectively. (Li et al. 2014).

In 2021, the MAQC published results of its largest project to date, known as SEQC2 (Sequencing Quality Control Phase 2) (Mercer et al. 2021). SEQC2, funded by the 21^st^ Century Cures Act, benefited from international participation of more than 300 contributing scientists from 150 industry, academic, and government organizations. It was divided into six areas of clinical application which used a variety of NGS technologies (DNA-seq, RNA-seq, Exome-seq, methylation-seq, etc.) for germline variant detection, cancer genomics, cell-free tumor DNA/biomarker discovery, and other precision medicine initiatives. Among the goals of SEQC2 toward analytical validation of transcriptomic data streams were to: 1) develop tangible and reproducible reference standards for NGS platforms; 2) benchmark the impact of experimental and bioinformatic variables on the generation and analysis of NGS data; and 3) evaluate inter- and intra-lab reproducibility of transcriptomic data derived from NGS technologies across different laboratories (Foox et al. 2021). The SEQC2 project significantly advanced understanding of the translational scientific infrastructure afforded by NGS technologies. The SEQC2 project yielded the scientific foundation that led to U.S. Food and Drug Administration (FDA) approvals of a number of NGS-based solid tumor tests as companion diagnostics (Li et al. 2021) utilized in patient therapy and precision oncology^18^. Most recently, FDA has approved NGS-based companion diagnostic (CDx) tests for the monitoring of advanced solid tumors using liquid biopsies, e.g., Guardant360® CDx^19^, and FoundationOne® Liquid CDx. Use of RNA-seq technologies in patient care settings demonstrates the degree of confidence by federal regulatory agencies, such as FDA, in utilizing reproducible and validated NGS workflows to advance human health protection.

## 3.3 DOSE CONCORDANCE OF TRANSCRIPTIONAL AND APICAL RESPONSES

Traditionally, subchronic or chronic duration toxicity studies, such as the two-year rodent bioassay, are conducted to inform the qualitative landscape of potential adverse health effects of environmental chemicals and to identify quantitative PODs considered in the derivation of reference values in human health assessments. However, given the general lack of traditional toxicity testing data and human health assessments for environmental chemicals, shorter duration animal studies combined with large scale molecular measurement technologies provide a significant opportunity to fill these gaps. Time course studies indicate that upon sustained exposure to stimuli, such as environmental chemicals, changes in cellular gene expression can occur within minutes to days (Tullai et al. 2007). Frequently, progression of gene expression changes following chemical exposure involves induction of genes associated with xenobiotic response, such as nuclear transcription factors that are critical mediators of a wide variety of key biological functions (e.g., stress responses, immune effects, and metabolic changes) that result in downstream protein production and physiologic responses, including adverse health effects [reviewed in (Fowler et al. 2011)].

Quantifying transcriptional changes provides an indication of chemical potency for producing biological perturbation(s). Indeed, multiple studies have evaluated the relationship between transcriptomic BMD(L) values and traditional tissue-, organ-, and organism-level BMD(L) values for adverse apical endpoints across a variety of exposure durations, treatments, routes of exposure, biological targets, and species [e.g., (Bercu et al. 2010; Chepelev et al. 2015; Clewell et al. 2011; Clewell et al. 2014; Dunnick et al. 2017; Gwinn et al. 2020; Jackson et al. 2014; Johnson et al. 2020; Labib et al. 2016; Lake et al. 2016; Recio et al. 2017; Shockley et al. 2020; Thomas et al. 2007; Thomas et al. 2012; Zhou et al. 2017)]. Collectively, these studies and others reviewed in this document demonstrated that transcriptomic BMD(L) values, when grouped by pathway, biological process, molecular function, or other biologically based sets of genes, showed good concordance with BMD(L) values for phenotypic apical effects from traditional animal-based toxicity studies. The ability to derive a BMD(L) value that indicates a coordinated gene expression response and its association with an adverse toxicological response are among the main principles necessary to apply transcriptomic data to quantitative human health assessments (Johnson et al. 2022).

## 3.4 IMPACT OF EXPOSURE DURATION ON TRANSCRIPTIONAL AND APICAL DOSE CONCORDANCE

One consideration for quantifying a transcriptomic POD from short-term in vivo studies is to determine the duration of exposure needed to inform adverse health effects that may develop in longer-duration (e.g., chronic) studies. Studies conducted across several organizations (i.e., EPA, Hamner Institutes, Health Canada, NTP, Corteva, and others) have experimented with different timepoints – ranging from 1 to 90 days – with the goal of comparing dose-concordance between gene set-based transcriptomic PODs and apical effect-based PODs from traditional toxicity test designs/exposure durations. One of the aims of these investigations has been to identify an “optimal” repeated dosing duration for transcriptomic assessment.

Multiple studies have compared apical effect and transcriptomic BMD values in subchronic studies (Bianchi et al. 2021; Clewell et al. 2011; Clewell et al. 2014; Dong et al. 2016; Thomas et al. 2011). In 2011, Thomas and colleagues exposed female mice for 90 days via gavage or inhalation to five chemicals^20^ that had been previously evaluated in conventional subchronic and/or chronic duration studies (e.g., by the NTP). Gene set-based transcriptomic BMD values from the target tissues (i.e., liver or lung) were compared to 90-day and two-year gross tissue and histopathology data. Both tissues showed concordance between the transcriptomic BMD(L) and the lowest apical BMD(L) values associated with histological or tissue weight change at those timepoints. All transcriptomic BMD values were within 8-fold (10-fold for the transcriptomic BMDL) of the lowest apical BMD value for both non-cancer and cancer effects. While overall the transcriptomic BMD values tended to be lower than apical effect values, there were instances where the opposite was true. In those cases, the transcriptomic BMD was no more than 3-fold higher than the apical effect BMD (Thomas et al. 2011). In another subchronic study, Dong and colleagues identified a transcriptomic BMD for furan in male rat liver tissue that was slightly higher (2-fold) than the time-matched BMD for the lowest histopathological endpoints of Kupffer cell pigmentation and hepatocyte apoptosis (Dong et al. 2016). When compared to two-year adenoma and carcinoma incidence data, the transcriptomic BMD was 30-fold more sensitive than the tumor-related BMD. Insufficient gene response in females prevented a similar comparison, which also coincided with prior observations of females being generally less sensitive to furan exposure (Dong et al. 2016). More recently, Bianchi and colleagues compared gene set-based transcriptomic BMD(L) values from male rats exposed to four agrochemicals^21^ for 90-days to the pathological effects at that time-point. Gene expression data were obtained from liver, kidney, or, in one case, both tissues, and transcriptomic PODs were compared to the apical, 90-day rat and two-year rat and mouse data regardless of target tissue or sex (Bianchi et al. 2021). When comparing species-matched results, the male transcriptomic POD was 1.2- to 14.1-fold lower than the apical effect POD for either sex in rats at 90 days. The subchronic transcriptomic POD values performed slightly less well when correlated with the two-year rodent data; yet these values were 1.3- to 22.9-fold lower (for all but one chemical, sulfoxaflor) than the apical POD. On average, the rat transcriptomic PODs tended to be within 10-fold of the lowest two-year, apical POD (Bianchi et al. 2021). Overall, these studies indicate that transcriptomic PODs provide reasonable estimates of apical effect PODs following subchronic exposures.

A larger proportion of studies have focused BMD modeling of transcriptomics from shorter-duration exposures (3- to 30-days) to inform carcinogenic mode of action and identify PODs (Bhat et al. 2013; Chepelev et al. 2017, 2018; Jackson et al. 2014; Labib et al. 2016; Labib et al. 2017; Moffat et al. 2015). Several studies had time-matched clinical and histopathological data for comparison with gene set-based transcriptional responses with many focused on the 28- or 30-day timepoint. For instance, a case study by Bhat and colleagues reported four tumorigenic conazoles (cyproconazole, epoxiconazole, propiconazole, and triadimefon) tested in male mice were differentiated from a non-tumorigenic conazole (myclobutanil) after 30 days of exposure with transcriptomic data, but traditional pathology data (liver weight, tumor burden) could not distinguish tumorigenic from non-tumorigenic conazoles at the 30-day time point (Bhat et al. 2013). The 30-day gene set-based transcriptomic POD values were the same as or within 2-fold of the time matched liver weight changes. For the tumorigenic conazoles, the gene set transcriptomic POD values were within 5-fold of the apical PODs based on hepatocellular carcinoma or adenoma for each chemical, which ranged from 2.1 mg/kg-day for cyproconazole to 270 mg/kg-day for triadimefon (Bhat et al. 2013). In another study that investigated furan, Jackson and colleagues demonstrated that transcriptomic PODs after 3 weeks of exposure in female mice were within 12-fold of the 90-day apical POD for hepatocyte cell death and equivalent to the two-year apical POD for hepatocellular adenoma (Jackson et al. 2014).

For the few studies with time-matched clinical and histopathological data at multiple early timepoints, there are indications that shorter studies are just as sensitive for determining apical PODs as longer duration studies. For instance, Moffat and colleagues explored the added value of combining transcriptomic data with traditional toxicity data in conducting a risk assessment of benzo(a)pyrene. Gene set level response data from 3- and 28-day mouse were related to lung, forestomach, and liver cancer development by either focusing on key events in carcinogenesis or using no a priori toxicity knowledge and using enriched gene sets (Moffat et al. 2015), similar to the approach employed by Thomas and colleagues (2011) except the 10^th^ percentile of all genes assigned to an Ingenuity Pathway Analysis gene set BMD was used instead of the median. Both the Moffat and Thomas approaches produced liver-based transcriptomic PODs after 3 days of exposure that were lower than the 28-day transcriptomic PODs by 6.7- and 26.5-fold for the key event and no a priori knowledge approaches, respectively, with the caveat that the 28-day transcriptomic data were obtained 3 days after the final exposure. The 3-day transcriptomic PODs were also lower compared to the chronic apical POD for liver tumors at 1.2 mg/kg-day. However, the gene set transcriptomic POD in the no a priori knowledge approach was slightly lower at 0.2 mg/kg-day than the transcriptomic POD using mode of action information at 1 mg/kg-day suggesting either approach could be useful for assessing the risk of chemicals that lack traditional toxicity testing data (Moffat et al. 2015). Another two studies in mice and rats investigating acrylamide-induced tumor development collected transcriptomic dose response data at 5, 15 and 31 days for comparison to two-year tumor data in the Harderian gland (the target tissue with the lowest apical POD), lung, and forestomach in mouse or the liver and thyroid (the target tissue with the lowest apical POD) in rat (Chepelev et al. 2017, 2018). Chepelev and colleagues (2017 and 2018) identified that 15 days was sufficient for identifying a transcriptomic POD consistent with thyroid and lung tumors for rat and mouse, respectively. Both were slightly higher than the apical PODs at 2.1- and 1.4-fold; however, there were insufficient gene expression changes after 5 days of exposure to identify a transcriptomic POD in either study, and 31 days of exposure were required to identify a transcriptomic POD from the Harderian gland which was within 2.3-fold of the apical POD for tumor development in the mouse (Chepelev et al. 2018). A related study focusing on acrylamide-related testicular toxicity also evaluated gene response data in the testes at 5, 15 and 31 days and found positive dose-related trends on days 5 and 31; however, only day-31 genes underwent transcriptomic BMD modeling. From this, a transcriptomic POD was identified for testes that was slightly lower than the No Observable Adverse Effect Level (NOAEL) for male reproductive toxicity, but was 6-fold higher than the BMDL values for other apical effects such as peripheral neuropathy (Recio et al. 2017). Gwinn and colleagues evaluated acrylamide in a 5-day transcriptomic study and found that the lowest median BMD value when summarized by gene set was equivalent to the lowest apical BMD for peripheral nerve degeneration in male rats (0.68 and 0.61 mg/kg-day, respectively)(Gwinn et al. 2020). Gwinn and colleagues also identified Harderian gland adenoma and adenocarcinoma as the apical effect with the lowest POD, which was less than 2-fold lower than the gene set level BMD (Gwinn et al. 2020). The difference between the Gwinn and Recio studies may be due to the tissue used for measuring gene response. Gwinn and colleagues used kidney and liver, which may be more indicative of systemic effects and could explain the lower transcriptomic BMD compared to the testes gene response from the Recio study.

A recent study by Johnson and colleagues examining the consistency in transcriptomic PODs across multiple timepoints provides support for using 5- to 30-day exposure durations to inform adverse effect PODs observed at timepoints beyond 30 days (Johnson et al. 2020). In this work, TG-GATES^22^ data were analyzed to compare transcriptomic and apical PODs across 79 chemicals for both a single dose and repeated dose study designs. Transcriptomic POD values from the liver of exposed male rats were used as the sentinel tissue to compare with the lowest apical PODs at the 29-day timepoint. The apical endpoints examined included histopathology in liver and kidney, body and organ weights, and clinical observations. The transcriptomic PODs were generally consistent across later timepoints (>4 days) relative to the 29-day apical POD values regardless of dosing scheme (r > 0.81 for the 4-, 8-, and 15-day timepoints). For the 51 chemicals with repeated dose data at the later timepoints, >90% had transcriptomic PODs within 10-fold of the lowest 29-day apical POD. Across dosing regimens and timepoints, the median absolute fold change in transcriptomic POD relative to the 29-day apical POD was approximately two (Johnson et al. 2020).

In one of the more thorough time course studies, Thomas and colleagues assessed the transcriptional response from six^23^ chemicals at multiple time points (5 days and 2, 4, and 13 weeks) in male or female rats across a range of target tissues (liver, thyroid, and bladder) and two oral exposure administration methods (gavage and feed) (Thomas et al. 2013b). The lowest transcriptomic BMD values when summarized by gene set remained stable across time. The transcriptomic BMD values correlated robustly with non-cancer phenotypic responses across all exposure durations from 5 days, 2, 4, and 13 weeks (r > 0.9) (Thomas et al. 2013b). For cancer-related effects, the transcriptional and tumor BMD values were also highly concordant. A reanalysis of the Thomas et al. 2011 and 2013 datasets compared 11 different approaches for calculating transcriptomic BMDs and identified multiple gene set and gene-based approaches that were in agreement with the traditional non-cancer and cancer apical BMD values (Farmahin et al. 2017). A slightly older study examining the time-course effects of paraformaldehyde across 1-, 4-, and 13-week exposure periods also demonstrated that the transcriptomic POD values from short-term exposures were only slightly higher than the subchronic transcriptomic POD, and both values were within 1.4-fold of the NOAEL for nasal tumor development (Andersen et al. 2010).

In a time course study examining the transcriptional and apical dose concordance in sensitive and non-sensitive species, Thomas and colleagues measured transcriptomic changes in female mouse and female rat lungs following 5 and 15 days of exposure to 2-chloro-1,3-butadiene (Thomas et al. 2013a). The transcriptional and apical concordance in BMDs and PODs was strong at both time points in the sensitive species (i.e., female mice); however, in the less sensitive species (i.e., female rat), the 5-day time point showed better dose concordance than the 15-day time point. At the 15-day time point in the female rat, the transcriptomic BMD and POD were lower than the apical BMD for lung tumors.

A significant number of studies have examined transcriptomic and apical dose concordance following exposures of 7 days or less. Lake and colleagues (2016) investigated the ability of transcriptomics to distinguish the differences in tumorigenic potency for three reference phthalates (diethylhexyl phthalate, di-n-octyl-phthalate, and butyl benzyl phthalate) with differing levels of peroxisome proliferator activated receptor α (PPARα) activation following 7 days of exposure. Transcriptomic POD estimates correctly stratified the phthalates according to tumorigenic potencies (Lake et al. 2016). Zhou and colleagues (2017) exposed mice to either trichloroethylene or tetrachloroethylene for 1-day and performed whole transcriptome RNA-Seq on livers and kidneys. In order to compare across species, they employed physiologically-based pharmacokinetic (PBPK) modeling to calculate human equivalent doses for mouse tissue-specific transcriptomic PODs as well as apical PODs from two-year rodent bioassays (Zhou et al. 2017). When considering established mode of action for these two chemicals, the median, human equivalent, transcriptomic PODs for liver and kidney were 10.4-fold (± 3.5 MAD) higher than the lowest, two-year, apical POD. Conversely, when the lowest median transcriptomic POD summarized by gene set was used for comparison, the values tended to be within 2.6-fold (median ± 1.2 MAD) of the lowest, two-year apical PODs (Zhou et al. 2017). Bercu and colleagues demonstrated that 2-day fenofibrate and up to 7-day methapyrilene exposures in female rats resulted in transcriptomic PODs that were either 12-fold lower or 8-fold higher than the apical PODs for hepatocellular carcinoma for each pharmaceutical, respectively (Bercu et al. 2010).

Numerous studies performed by the NTP and the DTT have included short-term transcriptomic studies for comparison to studies of longer duration (Catlin et al. 2018; Dunnick et al. 2017; Gwinn et al. 2020; NIEHS 2022a; Shockley et al. 2020). Initial studies from DNTP using a 5-day transcriptomic assay examined N,N-dimethyl-p-toluidine and toluidine in male rats. Dunnick and colleagues developed transcriptomic PODs by taking the mean BMDL from gene sets that had at least 5 genes altered (Dunnick et al. 2017). While this study itself did not directly compare transcriptomic PODs to apical PODs, for N,N-dimethyl-p-toluidine, the gene set with the lowest transcriptomic POD (2.0 mg/kg-day) was three times higher than the lowest apical POD (0.64 mg/kg-day) for respiratory metaplasia in male rats from the NTP bioassay (NTP 2022). Shockley and colleagues examined a series of brominated or phosphorylated flame retardants in 5-day transcriptomic assays. Two of these chemicals, decabromodiphenyl ether and 2,2’,4,4’-tetrabromodiphenyl ether, have IRIS values based on mouse neurobehavioral toxicity in which the apical POD used to derive the reference dose (RfD) is within a factor of 7 or less of the transcriptomic POD (Shockley et al. 2020). In a series of NIEHS reports, the DTT studied four phosphorylated flame retardants in 5-day transcriptomic studies. Of the four phosphorylated flame retardants, only tricresyl phosphate has a publicly available guideline study. The transcriptomic POD for tricresyl phosphate (10.1 mg/kg-day) (NIEHS 2022a) was approximately 2-fold lower than a guideline developmental toxicity study in rats^24^ (20 mg/kg-day) found in the European Chemicals Agency’s (ECHA) database.

In an expansive DNTP study, targeted gene expression measurements were made in the liver and kidneys of male rats following exposure to 18 chemicals or mixtures at 8 dose levels with a study duration of 5 days (Gwinn et al. 2020). The study used the S1500+ TempO-Seq transcriptomic platform (Mav et al. 2018). For the chemicals that had corresponding repeated dose toxicity studies in the same sex and species (i.e., male rats), the gene set with the lowest median transcriptomic BMD value from the liver or kidneys was within 10-fold of the lowest non-cancer apical BMD for >90% of tested substances, including apical BMD values from other organs. For cancer apical BMDs, transcriptomic BMD values from the liver or kidneys were within 10-fold of the lowest cancer apical BMD for >80% of tested chemicals or mixtures (15/18 substances). Notably, the concordance in transcriptomic and apical BMD values was not sensitive to differences in the toxicokinetic half-lives. The chemicals in the DNTP study had half-lives in male rats of hours (acrylamide and bromodichloroacetic acid) to weeks (perfluorooctanoic acid and the pentabromodiphenyl ether mixture DE-71). In the Gwinn et al. study, transcriptional changes and transcriptomic values in liver and kidney were identified for two botanicals, ginseng and milk thistle extract, as well as tetrabromobisphenol A, which had shown non-cancer or cancer-;related histopathological lesions in male rats in previously conducted two-year chronic bioassays (Gwinn et al. 2020). However, in the original NTP reports, tetrabromobisphenol A was reported to have a reduction in body weight at the middle and high dose levels (NTP 2014) and milk thistle extract showed a reduction in biliary hyperplasia and mixed cell infiltration at the high dose (NTP 2011). While the histopathological changes following exposure to milk thistle extract may not be considered adverse in a traditional assessment context, apical changes were present. When the chemicals or mixtures from the Gwinn et al. study were evaluated across species and sexes, the lowest male rat transcriptional BMD was within an order of magnitude of the lowest apical BMD in male and female rats and mice from the NTP chronic toxicity and carcinogenicity studies 82% of the time.

To illustrate the concordance of transcriptional BMD(L) from various exposure durations with apical BMD(L) from chronic toxicity and carcinogenicity studies, a scatter plot was created (Fig. 3-1). Studies included in the scatter plot and concordance analysis focused on those reporting both gene set-based BMD(L) values from 1- to 90-day exposures and chronic apical BMD(L). When all the studies were combined, the Pearson’s correlation coefficient for the transcriptomic BMD versus chronic, apical BMD was 0.820 with a log_10_ RMSD of 0.593 (log_10_ mg/kg-day) and a median absolute ratio^25^ of 2.4 ± 1.0 (MAD). For exposure durations of 5 days, the Pearson’s correlation coefficient for the transcriptomic BMD versus chronic, apical BMD was 0.760 with a log_10_ RMSD of 0.621 (log_10_ mg/kg-day) and median absolute ratio of 2.7 ± 1.3 (MAD). However, the 5-day exposure duration data contained a larger mix of chemicals where transcriptomic changes were not measured in the same tissue as the chronic, apical endpoint. For comparison, the RMSD values for the combined dataset are similar to the range of inter-study standard deviation estimates for the Lowest Observable Adverse Effect Levels (LOAELs) for systemic toxicity in repeated dose studies, approximated as residual RMSE in log10-mg/kg-day units [0.45-0.56; (Pham et al. 2020)]. The results suggest that the error associated with the concordance between the transcriptomic BMD values versus non-cancer and cancer apical BMD values is approximately equivalent to the inter-study variability in the repeated dose toxicity study itself. Data for the comparison in Figure 3-1 were obtained from studies published between 2010 and 2022 (Andersen et al. 2010; Bercu et al. 2010; Bhat et al. 2013; Bianchi et al. 2021; Cannizzo et al. 2022; Chepelev et al. 2017, 2018; Dong et al. 2016; Gwinn et al. 2020; Hester et al. 2016; Jackson et al. 2014; Labib et al. 2017; LaRocca et al. 2020; Moffat et al. 2015; Recio et al. 2017; Thomas et al. 2007; Thomas et al. 2011; Thomas et al. 2013a; Thomas et al. 2013b; Zhou et al. 2009).

Figure 3-1 Concordance between mouse or rat transcriptomic and chronic apical BMDs or BMDLs including carcinogenicity studies

(a.) Transcriptomic BMD values vs. two-year apical BMD values. (b.) Transcriptomic BMDL values vs. two-year apical BMDL values. Transcriptomic results from 1, 2, 3, 5, 6, or 7-day test durations are reported under the 5-day timepoint. Results from 15 and 21-day test durations are reported under the 15-day timepoint. Results from the 28, 29, 30, and 31-day exposure durations are reported under the 30-day timepoint, and results from the 90 and 91-day exposure durations are reported under the 90-day timepoint. Only studies with a transcriptomic BMD and/or BMDL and two-year apical BMD and/or BMDL were included in the graphs. For the transcriptomic BMD and/or BMDL, the median of the most sensitive gene set or datapoint most similar to the ETAP approach was used. If multiple tissues were investigated in the study, then the lowest transcriptomic BMD(L) across all tissues was selected. For the apical BMD(L), the lowest two-year BMD(L) reported for a chemical and species was used, which sometimes did not match the tissue used for obtaining the transcriptomic BMD(L). If the same chemical was independently tested in different studies, then the transcriptomic BMD(L) and associated apical BMD(L) for each study was included. Only dose matched metrics were used. For instance, if the apical BMD(L) was in mg/kg-day, then the transcriptomic BMD(L) reported in mg/kg-day was used, but if the apical BMD(L) was in ppm, then the transcriptomic BMD(L) reported in ppm was used. The header for each facet of the figure indicates the timepoint in days (d) for the transcriptomic BMD(L). HED is human equivalent dose. The solid line indicates a perfect concordance at 1. The dashed lines represent 10-fold difference between the BMD(L) values.

## 3.5 IMPACTS OF CHEMICAL MODE-0F-ACTION ON TRANSCRIPTIONAL AND APICAL DOSE CONCORDANCE

The studies examining transcriptomic PODs in shorter-term exposure durations typically focused on how well they predict apical PODs from chronic, subchronic and shorter-term toxicity studies. The chemicals evaluated cover a broad set of bioactivities. For example, Johnson and colleagues examined 79 chemicals, most of which were pharmaceuticals. Included in this list were neuroactive chemicals (e.g., diazepam, phenobarbital, haloperidol), anticancer agents (e.g., doxorubicin, etoposide, cyclophosphamide), antibiotics (e.g., isoniazide, tetracycline), and several other classes of drugs (Johnson et al. 2020). These chemicals demonstrate a broad range of molecular initiating events that cover receptor-mediated responses, enzyme inhibition and DNA alkylation. In contrast, the chemicals examined by Thomas and colleagues (2013) were mainly industrial chemicals with unknown modes of action. The studies by the DNTP (Dunnick et al. 2017; Gwinn et al. 2020; Shockley et al. 2020) examined genotoxic chemicals (e.g., acrylamide, furan, N,N-dimethyl-p-toluidine), receptor-mediated and endocrine-active toxicants (e.g., perfluorooctanoic acid, ethinyl estradiol; di(2-ethylhexyl)phthalate) as well as chemicals with uncertain modes of action (e.g., 3.3’,4,4’-tetrachlcoroazobenzene, hexachlorobenzene, bromodichloroacetic acid, decabromodiphenyl ether). While there has not been a systematic approach to evaluating transcriptional and apical dose concordance across specific molecular initiating events or modes of action, the diversity of chemicals evaluated in these studies has covered sufficient biological space to suggest that gene set-based transcriptomic PODs from short-term in vivo studies would work well for most general and target organ toxicities of interest to risk assessors.

Currently, studies evaluating the concordance of transcriptomic PODs with apical endpoints have primarily focused on subchronic and chronic toxicity studies. Additional studies may be required to evaluate how well transcriptomic PODs from adult animals predict apical PODs for other health domains, such as developmental toxicity, reproductive toxicity, immunotoxicity, and neurotoxicity. Notably, a previous retrospective analysis demonstrated that apical data from subchronic toxicity studies can predict effects on fertility (Dent 2007), while a separate retrospective analysis showed less than a two-fold difference in NOAEL values between rat subchronic studies and two-generation reproductive and developmental studies (Janer et al. 2007). Given the concordance between transcriptomic PODs from short-term studies and apical PODs from subchronic and chronic toxicity studies, these two retrospective analyses suggest that transcriptomic PODs may also be protective of apical PODs for other toxic effects.

Despite multiple efforts to relate gene set alterations to apical responses, there are few toxicities for which there is a consensus for causal relationships between gene set changes leading to these apical responses. It should be noted that, in studies examining the time course of transcriptional changes, different gene sets were altered at different time points, yet the transcriptomic BMD(L) values remained generally consistent over time (Johnson et al. 2020; Thomas et al. 2013b).

## 3.6 SCOPE OF CHEMICAL FUNCTIONAL USE, PROPERTIES, AND TOXICOKINETIC PARAMETERS FOR CHEMICALS WITH TRANSCRIPTIONAL AND APICAL DOSE CONCORDANCE

The chemicals evaluated in short-term transcriptomic studies have included pharmaceuticals (Bercu et al. 2010; Gwinn et al. 2020; Johnson et al. 2020), pesticides (Bhat et al. 2013), flame retardants (Gwinn et al. 2020; Shockley et al. 2020), disinfection by-products (Gwinn et al. 2020; Shockley et al. 2020), persistent organic pollutants (Dunnick et al. 2017; Gwinn et al. 2020), high production volume chemicals (Gwinn et al. 2020; Thomas et al. 2013b), solvents (Catlin et al. 2018; Gwinn et al. 2020) and botanicals (Catlin et al. 2018; Gwinn et al. 2020). These substances not only have diverse commercial uses, but also encompass a large range of physicochemical properties. For comparison, a subset of physicochemical properties was compared between the 140 chemicals in the transcriptomic studies in the literature review and the chemicals on the TSCA active inventory; however, not all chemicals on the TSCA active inventory have defined structures, nor are physicochemical properties able to be predicted for all chemicals. Nonetheless, while the full range for each property was typically larger in the TSCA active inventory, the 10^th^ and 90^th^ percentiles were similar for both sets of chemicals suggesting that most of the distribution in properties were similar (Table 3-1). Apart from the physicochemical properties, the toxicokinetic parameters also vary significantly in this group of chemicals. For example, many of the pharmaceuticals evaluated have elimination half-lives of hours (caffeine, ethanol) (Johnson et al. 2020), while some of the industrial chemicals studied have elimination half-lives of months in rodents (Gwinn et al. 2020; Shockley et al. 2020). While many of the pharmaceuticals studied are extensively metabolized, some of the industrial chemicals such as perfluorooctanoic acid and decabromodiphenyl ether are poorly metabolized, if at all. The range of physicochemical and toxicokinetic properties of the chemicals studied suggests that short-term transcriptomic studies can provide reasonable estimates of apical PODs for a broad range of chemicals and substances.

Table 3-1 Predicted physicochemical properties of the chemicals evaluated in the in vivo transcriptomic studies in comparison with chemicals on the TSCA active inventory^a^

Physicochemical Property | Median | Minimum | Maximum | 10^th^ Percentile | 90^th^ Percentile
Chemicals Evaluated in In Vivo Transcriptomic Studies
Molecular Mass (g/mol) | 272.04 | 46.07 | 1202.64 | 132.12 | 426.12
LogK_ow_ | 2.85 | -1.78 | 8.10 | -0.29 | 5.76
Vapor Pressure (mmHg) | 3.18e-07 | 1.53e-11 | 5.95e02 | 5.36e-10 | 1.34e00
Henry’s Law (atm-m3/mol) | 4.66e-08 | 6.84e-12 | 1.77e-02 | 1.39e-10 | 3.23e-04
Water Solubility (mol/L) | 4.00e-04 | 1.05e-10 | 3.77e01 | 8.54e-07 | 3.27e-01
Chemicals on the TSCA Active Inventory
Molecular Mass (g/mol) | 221.03 | 2.02 | 4506.92 | 117.15 | 558.19
LogK_ow_ | 2.38 | -5.08 | 10.28 | -0.9 | 5.64
Vapor Pressure (mmHg) | 2.78e-04 | 3.06e-14 | 2.84e09 | 9.78e-10 | 5.26e00
Henry’s Law (atm-m3/mol) | 2.57e-07 | 2.53e-12 | 3.29e01 | 2.19e-10 | 5.43e-04
Water Solubility (mol/L) | 2.79e-03 | 6.84e-14 | 3.77e01 | 1.26e-06 | 1.19e00

a Predicted physicochemical properties were obtained from the EPA CompTox Chemicals Dashboard using the OPERA model. Physicochemical properties were not able to be predicted for all chemicals.

## 3.7 IMPACTS OF ROUTE OF EXPOSURE AND TISSUE SELECTION ON TRANSCRIPTIONAL AND APICAL DOSE CONCORDANCE

Common routes of chemical exposure in traditional toxicity studies include inhalation, ingestion, and absorption through the skin and eyes. Studies that have derived transcriptomic PODs have generally used oral exposures including feed, gavage, and drinking water. For the inhalation route, Thomas and colleagues used inhalation exposures for 3 chemicals (propylene glycol mono-t-butyl ether, methylene chloride, and naphthalene) (Thomas et al. 2011) and Andersen and colleagues performed time course inhalation studies using formaldehyde (Andersen et al. 2008). In addition, Thomas and colleagues evaluated cross-species concordance in transcriptomic PODs following inhalation exposure to 2-chloro-1,3-butadiene for 5 and 15 days (Thomas et al. 2013a). No studies were identified that evaluated transcriptomic PODs for chemicals in which dermal or ocular exposures were employed. For inhalation and oral exposures, the available studies suggest that the route of exposure does not appear to significantly alter the relationship between the transcriptomic and apical POD (Fig. 3-1). For oral studies across all exposure durations, the Pearson’s correlation coefficient for the transcriptomic BMD versus chronic, apical BMD was 0.762 with a log_10_ RMSD of 0.618 and median absolute ratio of 2.2 ± 0.9 (MAD). For inhalation studies, the Pearson’s correlation coefficient for the transcriptomic BMD versus chronic, apical BMD was 0.933 with a log_10_ RMSD of 0.495 and median absolute ratio of 2.7 ± 1.2 (MAD).

In guideline chronic toxicity and carcinogenicity studies, approximately 40 different tissues from rats are typically selected for histopathological analysis. Transcriptional analysis of all 40 tissues in male and female rats across an expanded dose range would be very costly. To control costs, the majority of the published studies evaluating the transcriptomic and apical dose concordance focused only on a few selected target tissues as defined by endpoints in subchronic or chronic guideline studies. A subset of studies across 19 chemicals have evaluated use of liver and/or kidney as sentinel tissues for determining transcriptomic PODs (Bianchi et al. 2021; Gwinn et al. 2020; Thomas et al. 2011; Thomas et al. 2012; Zhou et al. 2017). The liver and kidneys were chosen as sentinel tissues for several reasons. First, the liver is the principal site of xenobiotic metabolism immediately after chemical absorption from the gastrointestinal tract, and it has the largest supply of biotransformation enzymes (e.g., cytochromes P450) of all organs in the body. Therefore, the liver has a key role in xenobiotic detoxification. For some xenobiotics, hepatic metabolism may result in activation of the chemical. For example, the carcinogen benzo(a)pyrene must be oxidized to its ultimate carcinogenic form, a diol epoxide. Thus, the liver is a key sentinel tissue for transcriptomic analysis due to its role in xenobiotic metabolism. Second, the kidney is frequently selected as a sentinel tissue because it receives about 20% of the cardiac output. The kidney functions to remove xenobiotics and their metabolites from the blood and excrete them from the body through urine. Finally, the kidney can also transport chemicals into the tubular lumen of the kidney where absorption from the lumen can also occur. Across the 19 chemicals that have been studied using liver and kidney as sentinel tissues, the combined data from these studies show slightly lower concordance between the transcriptomic and apical PODs (Fig. 3-2). The Pearson’s correlation coefficient for the transcriptomic BMD versus chronic, apical BMD for the sentinel tissues was 0.797 with a log_10_ RMSD of 0.678 and median absolute ratio of 3.6 ± 2.0 (MAD). However, from a cost and efficiency standpoint, the results demonstrate that the use of a smaller set of sentinel tissues can provide predictions of the apical PODs within approximately ± 10-fold.

Figure 3-2 Concordance of transcriptomic and apical BMD(L)s for liver and kidney as sentinel tissues

The concordance between the transcriptomic BMD(L)s and chronic apical BMD(L)s is based on transcriptomic data from surrogate tissues (i.e., liver or kidney) using data from Bianchi et al. 2021; Chepelev et al. 2017; Gwinn et al. 2020; Thomas et al. 2011; Zhou et al. 2017. The data is presented as BMDs unless BMDLs were the only values reported in the manuscript as for Bianchi et al. 2021 and Zhou et al. 2017. The apical BMD(L)s are all derived from two-year chronic bioassays, while the transcriptomic BMD(L)s are derived from studies using exposure durations from 1 - 90 days. The solid line indicates a perfect concordance at 1 and the dashed lines represent a 10-fold difference from the BMD(L).

## 3.8 IMPACTS OF TECHNOLOGY PLATFORM ON TRANSCRIPTIONAL AND APICAL DOSE CONCORDANCE

Large scale gene expression technologies have evolved over the past two decades from targeted, fluorescent intensity-based methods used by microarrays to both targeted and untargeted, count-based RNA-Seq approaches. RNA-Seq has the added benefit of measuring a larger dynamic range in gene expression measurements. In a recent analysis that compared microarrays versus RNA-Seq in a dose response experiment, Black and colleagues (2014) reported similar results. In that study, bromobenzene-induced fold changes in genes measured by microarray and RNA-Seq correlated well with each other across dose-levels despite differences in platform-specific normalization procedures (Spearman correlation coefficient 0.65 to 0.77). RNA-Seq tended to identify more significant genes across all dose-levels when fold-change and statistical filters were applied to the dataset. The gene set based transcriptomic BMDs between microarray and RNA-Seq were similar at 78 – 80 and 57 – 76 mg/kg-day, respectively, with the ranges defined by the normalization approach employed (Black et al. 2014). Both technologies provided gene set-based transcriptomic BMD values similar to the apical BMD of 96.8 mg/kg-day (Black et al. 2014).

As RNA-Seq has become more cost effective, it has replaced microarray-based gene expression methods as the main platform for assessing genome-wide changes in gene expression. Among RNA-seq approaches, the BioSpyder TempO-Seq platform combines some of the beneficial attributes of RNA-Seq dynamic range with targeted gene detection inherent to microarrays (Yeakley et al. 2017). The short, equal length probes used by TempO-Seq circumvent issues of read length biases found in RNA-Seq studies while focusing sequencing reads on probes, thereby reducing assay cost (Yeakley et al. 2017). Several studies demonstrate the comparability between TempO-Seq, RNA-Seq, and microarray in detecting dose-dependent alterations in chemically induced gene expression changes making it a cost-effective platform for transcriptomic potency assessments. Bushel and colleagues showed that TempO-Seq performed similarly to microarray and RNA-Seq with respect to analysis of the SEQC transcriptomics data (Bushel et al. 2018).

The studies examining the relationship between transcriptional and apical BMD(L)s reviewed in this report employed different platforms (i.e., microarrays, RNA-Seq or TempO-Seq) to evaluate transcriptional changes. While these studies also examined different chemicals using different exposure paradigms, the concordance between transcriptomic and apical BMD(L) were generally not influenced by the technology used to evaluate transcriptional changes (Figure 3-3).

Figure 3-3 Concordance of transcriptomic and apical BMD(L)s across transcriptomic platforms

Data was obtained from (Andersen et al. 2010; Bercu et al. 2010; Bhat et al. 2013; Bianchi et al. 2021; Cannizzo et al. 2022; Chepelev et al. 2017, 2018; Dong et al. 2016; Gwinn et al. 2020; Hester et al. 2016; Jackson et al. 2014; Labib et al. 2017; LaRocca et al. 2020; Moffat et al. 2015; Recio et al. 2017; Thomas et al. 2007; Thomas et al. 2011; Thomas et al. 2013a; Thomas et al. 2013b; Zhou et al. 2017). The data is presented as BMDs unless BMDLs were the only values reported in the manuscript as for Bhat et al. 2013; Bianchi et al. 2021; and Zhou et al. 2017. While the apical BMD(L)s all are derived from two-year chronic bioassays, the transcriptomic BMD(L)s are derived from studies using exposure durations from 1 - 90 days. The solid line indicates a perfect concordance at 1, and the dashed lines represent a 10-fold difference from the BMD(L). Orange colored symbols represent paired data from experiments where the same samples underwent microarray and RNA-Seq or TempO-Seq and RNA-Seq analyses.

## 3.9 SUMMARY OF TRANSCRIPTIONAL AND APICAL DOSE CONCORDANCE

In studies spanning over a decade, researchers have evaluated the concordance of short-term transcriptomic BMD(L)s and apical BMD(L) for over a hundred chemicals. Some studies were hypothesis-based mechanistic studies [e.g., (Dunnick et al. 2017; Geter et al. 2014; Moffat et al. 2015)], while others were more agnostic of the specific mechanisms and evaluated general concordance across larger, more diverse sets of chemicals [e.g., (Gwinn et al. 2020; Johnson et al. 2020; Thomas et al. 2012)]. Known target tissues were often evaluated [e.g., (Dunnick et al. 2017; Thomas et al. 2013b)], while others employed sentinel tissues such as the liver and kidney (Gwinn et al. 2020; Johnson et al. 2020). Exposure durations ranged from 1- to 90-days and the chemical, biological, and toxicological space examined covers much of the known chemistries and toxicities of concern by EPA and other entities that assess environmental chemicals. Even though these studies were not coordinated, the comparison across studies indicates that transcriptomic PODs from short-term in vivo studies provide robust estimates of apical PODs from traditional chronic rodent toxicity studies. The log_10_ RMSD of 0.593 (log_10_ mg/kg-day) for the 1- to 90-day transcriptomic BMD values versus chronic apical BMD values in the combined data set was similar to the range of inter-study standard deviation estimates for the LOAELs for systemic toxicity in repeated dose studies, approximated as residual RMSE in log10-mg/kg-day units [0.45-0.56; (Pham et al. 2020)]. Overall, the results suggest that the error associated with the concordance between the transcriptomic BMD values versus non-cancer and cancer apical BMD values is approximately equivalent to the inter-study variability in the repeated dose toxicity study itself.

14 The BMD(L) abbreviation is used in this document to define the combination of benchmark dose (BMD) and/or benchmark dose lower confidence bound (BMDL).

15 EPA BMDS software can be found at: https://www.epa.gov/bmds

16 A gene set is defined as pathway, biological process, molecular function, or other biologically based set of genes.

17 The guidance document and template for the OECD Omics Reporting Framework can be found at: https://www.oecd.org/chemicalsafety/testing/omics.htm

18 The list of FDA approved nucleic acid tests can be found at: https://www.fda.gov/medical-devices/in-vitro-diagnostics/nucleic-acid-based-tests#top

19 The news release can be found at: https://www.fda.gov/news-events/press-announcements/fda-approves-first-liquid-biopsy-next-generation-sequencing-companion-diagnostic-test

20 The five chemicals were: 1,4-dichlorobenzene; 1,2,3-trichloropropane; propylene glycol mono-t-butyl ether; naphthalene; and methylene chloride.

21 The four chemicals were triclopyr acid; sulfoxaflor; pronamide; and fenpicoxamid.

22 TG-GATEs (Toxicogenomics Project-Genomics Assisted Toxicity Evaluation System) is a public transcriptomic genomic database resulting from two joint government-private sector projects (H14-Toxico-001 and H19-Toxico-001) organized by the Japanese National Institute of Biomedical Innovation, National Institute of Health Sciences, and multiple pharmaceutical companies. The project generated gene expression and toxicity data in rats and primary cultured hepatocytes of rats and humans following exposure to 170 compounds in dose response, of which 79 compounds that met filtering criteria were utilized by Johnson et al. (2020).

23 The six chemicals were 1,2,4-tribromobenzene; bromobenzene; 2,3,4,6-tetrachlorophenol; 4,4’-methylenebis (N,N-dimethyl) benzenamine, N-nitrosodiphenylamine, hydrazobenzene.

24 ECHA REACH Dossier at: https://echa.europa.eu/registration-dossier/-/registered-dossier/16010

25 The absolute ratio between a and b is defined as maximum{a/b, b/a}.