# 2 BACKGROUND

## 2.1 WORLDWIDE AND DOMESTIC CHEMICAL LANDSCAPE

Modern societies are reliant upon chemicals to provide raw inputs for agriculture and manufacturing processes, with over 95% of manufactured goods and articles estimated to be reliant upon some form of industrial chemical process (OE 2019). A recent survey of chemical registries in 19 countries or regions found that greater than 350,000 chemicals and mixtures of chemicals were registered in one or more inventories (Wang et al. 2020). While large, this estimate of the combined worldwide chemical inventory is likely to be an undercount, as the inventories from which these numbers were derived do not include unintentionally produced materials (including unreacted intermediates, by-products, or degradation products), and the requirements of mass-production thresholds for registration lead to exclusion of certain manufactured chemicals from inventory lists. Domestically, the 2022 Toxic Substances Control Act (TSCA) chemical inventory contained more than 86,000 chemicals, of which approximately 42,000 are considered commercially active^1^. However, the global and domestic inventory numbers are a snapshot in time and trends in chemical production and use continue to rise (EEA 2018). The result of the historical, current, and future trends in chemical production is a substantial and increasing number of chemicals for regulatory agencies, such as the EPA, to evaluate for human health risks.

## 2.2 TOXICITY TESTING DATA LANDSCAPE

Understanding the human health impacts of exposure to chemicals requires testing and access to toxicity data. To evaluate the potential human health risk(s) of chemicals, assess potential impacts on the environment, and approve chemicals for certain uses, the EPA uses information from a broad range of animal studies, in conjunction with human data when available. While EPA and other federal agencies are working on the development and application of New Approach Methodologies (NAMs) to evaluate the potential human health hazards of chemicals (EPA 2021; NASEM 2007), toxicity testing has traditionally been performed in animal studies that employ varying exposure durations and that consider different health effect domains. The guideline animal studies include general acute, subchronic, and chronic repeat-dose toxicity studies as well as more targeted study designs such as those focused on neurotoxicity, reproductive toxicity, immunotoxicity, and developmental toxicity. The requirements for conducting these tests vary depending on the intended use of the chemical and specific statutes governing those uses. For example, conventional food-use pesticide active ingredients require a full battery of animal toxicology studies. In contrast, no specific animal tests are required for registering commercial and industrial chemicals regulated under TSCA.

To understand the overall landscape of toxicity testing data relevant to human health, the availability of testing data can be tallied across different sets of chemicals that are representative of those that are present in our environment, waste streams, contaminants of immediate and emerging concern, human bodies, and commerce. For chemicals in the environment, the EPA Multimedia Monitoring Database^2^ identifies chemicals in a diverse range of environmental and biological media (Isaacs et al. 2022). Databases of chemicals identified in biosolids^3^ and produced water^4^ (Danforth et al. 2020) provide information on substances identified in human waste and by-products derived from oil and gas extraction. For contaminants of immediate and emerging concern, the Organization for Economic Cooperation and Development (OECD) database of per- and polyfluoroalkyl substances (PFAS)^5^ provides a comprehensive list of PFAS substances that may have been on the global market at some point in time (OECD 2018). A database of the blood exposome^6^ that is filtered for chemicals on the TSCA inventory provides a list of non-pesticide exogenous chemicals that may be present in the human body (Barupal and Fiehn 2019). Finally, the TSCA active inventory provides substances that are currently active in US commerce^7^. Among chemicals in each of these sets, the maximum fraction of chemicals with any of the toxicity tests is 44% for chemicals in the blood exposome (Fig. 2-1). This suggests that more than half of chemicals identified in the blood have no toxicity testing data. Contaminants of immediate and emerging concern represented by PFAS are highly understudied, with only 1% PFAS substances having any available toxicity data. The more specialized toxicity tests, such as those assessing developmental toxicity, reproductive toxicity, immunotoxicity, neurotoxicity, and carcinogenicity, never exceed 30% among these representative sets of chemicals. For those chemicals identified in environmental media, only 43% have been subjected to any of the toxicity tests, while only 15% of chemicals in US commerce have been similarly tested. The results from the combined analyses on these representative sets highlight the limited human health toxicity information available to regulatory agencies, such as the EPA, on substances in the environment and to which humans are likely exposed.

Figure 2-1 Bar graph depicting the percentage of chemicals with different toxicity tests across various representative chemical sets

The sets of chemicals were selected to represent substances found in environmental media (Multimedia Monitoring Database), different waste streams (produced water from oil and gas extraction; biosolids), the human body (TSCA subset of the blood exposome), contaminants of emerging concern (OECD PFAS list), and commerce (TSCA active inventory). The ‘Systemic Repeat Dose’ toxicity test includes repeat dose studies of subchronic and chronic duration. The ‘Any’ category is the union of unique chemicals across the various study types. The total percentages of chemicals across study types may not equal the total percentage in ‘Any’ given that chemicals may have multiple different studies. The percentages of chemicals with toxicity tests were calculated based on the respective studies in ToxValDB v9.4.

## 2.3 HUMAN HEALTH ASSESSMENT LANDSCAPE

Human health assessments are developed to identify chemical exposure levels likely to be without appreciable risk of deleterious effects during an individual’s lifetime. These assessments inform a broad range of regulatory decisions, such as setting water quality standards or remediation levels at contaminated sites, restrictions on use, and standards for manufacturing, disposal, and air emissions. The lack of traditional repeated dose toxicity study data for most chemicals is one of the factors that impedes hazard identification and dose response assessment, including identification of points of departure (PODs)^8^ and derivation of corresponding reference values, which underpin human health risk assessments. Other factors that have impacted the development of human health assessments include the time and resources required to perform and review the studies, derive the resulting reference value, and publish the assessment. For example, it takes the EPA approximately 15 to 36 months to review the testing results of a single conventional agricultural pesticide following the data collection phase^9^. For industrial and commercial chemicals, the development of human health assessments can often take 4 years or more (Krewski et al. 2020), while more complex assessments can take substantially longer (NASEM 2009). These time estimates do not include performing the toxicity tests that the assessments rely upon for informing the derivation of human health reference values. The downstream consequences of the insufficient toxicity data, as well as the time and resources required to develop human health assessments, result in fewer chemicals with reference values for regulatory applications. To provide a picture of the human health assessment landscape, the availability of human health assessments from EPA and the Agency for Toxic Substances and Disease Registry (ATSDR) were tallied across the same sets of representative chemicals highlighted in Figure 2-1. These data are depicted in Figure 2-2. Across all the sets of chemicals, the maximum percentage of chemicals with a human health assessment were those identified in environmental media at 24%. For chemicals in biosolids, approximately 23% have human health assessments, while 11% of chemicals identified in human blood have assessments. Among chemicals on the TSCA active inventory, fewer than 2% of chemicals have human health assessments and 0.2% of the OECD list of PFAS have assessments. The overall conclusion from this comparison is that there remains a substantial number of chemicals in the environment and to which humans are likely exposed that do not have human health assessments. Filling this gap with traditional toxicity tests and chemical assessment workflows would require multiple decades and substantial resources to complete.

Figure 2-2 Bar graph depicting the percentage of chemicals with human health assessments from US federal agencies across various representative chemical sets

The sets of chemicals were selected to represent substances found in environmental media (Multimedia Monitoring Database), different waste streams (produced water from oil and gas extraction; biosolids), the human body (TSCA subset of the blood exposome), contaminants of emerging concern (OECD PFAS list), and the economy (TSCA active inventory). The percentages of chemicals with human health assessments were calculated based on the overlap with chemicals with non-cancer assessments in the EPA Integrated Risk Information System (IRIS) database, EPA Provisional Peer Reviewed Toxicity Values (PPRTV), Agency for Toxic Substances and Disease Registry (ATSDR) Minimum Risk Levels (MRL), EPA Office of Water Drinking Water Standards (OW DWS), and Office of Pesticide Program (OPP) risk assessments. The ‘Any’ category is the union of unique chemicals across the various assessment types. The total percentages of chemicals across assessment types may not equal the total percentage in ‘Any’ given that chemicals may have multiple different assessments (e.g., a chemical may have an IRIS and ATSDR MRL).

## 2.4 DEVELOPMENT OF THE EPA TRANSCRIPTOMIC ASSESSMENT PRODUCT (ETAP) TO ADDRESS THE HUMAN HEALTH ASSESSMENT GAP

Transcriptomics is the large-scale measurement of gene expression changes, and its application to toxicology enables broad characterization of the biological processes and pathways that may be impacted following exposure to a chemical. The technology has matured and has become broadly available and reproducible. Standardized methods and software applications have been developed for analyzing transcriptomic changes as a function of dose using methods traditionally applied in chemical risk assessment. In addition, a substantial body of research – detailed in Section 4 - has demonstrated that doses causing coordinated transcriptional changes are concordant with doses causing adverse apical^10^ effects in traditional toxicity studies, underscoring its potential application to regulatory decision making.

To help meet the need for toxicity testing and human health assessment of chemicals, the EPA is proposing to develop transcriptomic reference values (TRV) for use in EPA Transcriptomic Assessment Products (ETAP). The TRV is defined as an estimate of a daily oral dose to the human population that is likely to be without appreciable risk of adverse non-cancer health effects over a lifetime. The TRV is derived from a transcriptomic POD with uncertainty factors (UFs) applied to reflect limitations of the data used. The transcriptomic POD is defined as the dose at which there were no coordinated transcriptional changes that would indicate a potential toxicity of concern. The coordinated transcriptional changes used to identify the POD do not necessarily discriminate between specific hazards, adverse or adaptive effects, nor are they used to infer a mechanism or mode of action. The ETAP is intended to be applied to substances with no existing or publicly accessible repeated dose toxicity studies or human evidence suitable for use as a POD and reference value derivation. The ETAP may be updated to incorporate new data or methodologies that might impact the TRV or retired if traditional toxicity studies and an associated human health assessment are published.

The ETAP consists of three primary components: 1) initial database searches and systematic evidence map development; 2) short-term (5-day) in vivo transcriptomic study and POD determination; and 3) assessment development and reporting. The initial database searches and systematic evidence map are used to verify the lack of suitable in vivo experimental animal toxicity studies or human epidemiological studies. The transcriptomic PODs^11^ obtained from the short-term in vivo study in rodents are used in the derivation of a TRV through application of uncertainty factors (UFs) consistent with human health risk assessment practice in the EPA (EPA 2022). The values of the individual UFs and the overall composite uncertainty factor are the same across the individual ETAP assessments due to the standardized nature of the transcriptomic studies and data analysis procedures. The results from the systematic evidence mapping, 5-day transcriptomic study, and TRV derivation are compiled and reported in a standard ETAP template. A main concept of the ETAP is that the underlying methods and data analysis procedures are more standardized and structured than typical toxicity test guidelines and human health assessment documents, and the decision context is narrowly focused on substances with no existing or publicly accessible repeated dose toxicity studies or human evidence suitable for use as a POD and reference value derivation. Due to the standardized methods, the ETAP includes a streamlined review process that is intended to facilitate the rapid development, execution, and release of the human health assessments.

## 2.5 VALUE OF INFORMATION (VOI) ANALYSIS OF THE POTENTIAL PUBLIC HEALTH AND ECONOMIC TRADE-OFFS OF ETAP

A key aspect of public health decision-making with respect to potentially toxic chemicals present in the environment involves the choice between making an immediate decision with currently available information versus delaying a decision until additional data are collected and analyzed. This choice is often informed by the urgency of the public health need and the costs, in terms of both time and resources, of acquiring additional relevant information that may lead to decisions with less uncertainty. The US National Academies of Sciences, Engineering, and Medicine (NASEM), in its report Science and Decisions: Advancing Risk Assessment, reflected that time is a major and rarely acknowledged factor in risk assessment and that additional studies may reduce uncertainty, but the delay can have significant impacts on society and communities who are exposed while awaiting the results (NASEM 2009). The NASEM Committee recommended the development of a value of information (VOI) analysis to provide a more objective decision framework to evaluate the potential impact of new information on a particular decision or proposed changes in risk assessment activities (NASEM 2009). Given the limited human health toxicity information available on chemicals present in our environment, waste streams, human bodies, and commerce, as well as the need to gain efficient insight into contaminants of immediate and emerging concern, it is important to evaluate the VOI that new testing and human health assessment strategies may offer.

EPA ORD has developed a VOI framework that considers the public health and economic trade-offs associated with uncertainty, duration, and cost of chemical toxicity testing (Hagiwara et al. 2022). The VOI framework was used in a case study to evaluate public health and economic value of the short-term in vivo transcriptomic study and ETAP compared to a two-year rodent bioassay and traditional human health assessment (THHA) process (EPA 2024a). Both the ETAP and the THHA result in the derivation of a reference value that represents the daily dose of a chemical substance for which exposure to humans would be unlikely to result in an adverse health effect following oral exposure. The ETAP and THHA process differ in the cost of the study, duration of the study and assessment process, and the degree of uncertainty around the POD, with ETAP having the inherently shorter-duration and lower cost assay, but with the trade-off of presumed greater uncertainty. The comparison was performed for various combinations of exposure conditions, health endpoints, control costs, population characteristics, and decision types. A total of 306 combinations of input parameters were developed as scenarios to capture the diverse range of characteristics and contexts for chemicals in the domain of ETAP. The scenarios and associated parameters were informed by empirical data and real-world information where available. This case study is the subject of a separate Board of Scientific Counselors (BOSC) review; however, the results of the analysis were intended to complement the scientific review of the ETAP by providing the potential socioeconomic impacts of the draft human health assessment if implemented.

The results of the case study showed that ETAP was favored over THHA in the majority of scenarios examined and across multiple VOI metrics. The benefit-risk decision maker chooses to mitigate exposure if the reduction in health cost (or increased health benefit) outweighs the associated cost of control. When evaluated by a benefit-risk decision maker, 81% of the scenarios favored ETAP, while the remaining 19% favored neither ETAP nor THHA. The target-risk decision context takes regulatory action to mitigate exposure whenever the risk exceeds a prespecified target risk level. The target-risk decision context does not consider the cost of the exposure mitigation efforts. When evaluated by a target-risk decision maker, between 89 and 99% of the scenarios favored ETAP depending on the VOI metric evaluated with 8% of the scenarios favoring neither ETAP nor THHA. The median difference in the expected net benefit of sampling (ENBS), which considers the reduction in total costs from the additional testing and assessment activities adjusted for delay and the cost of testing, was approximately $47 billion for the benefit-risk decision context and $82 billion for the target-risk decision context^12^. Negative values for the ENBS were frequently observed for THHA and the benefit-risk decision context suggesting that the delay and costs associated with decision-making for the traditional toxicity testing and human health assessment process are greater than the eventual benefit. In contrast, the ETAP less frequently had a negative ENBS for the benefit-risk decision context, suggesting that the benefit gained by collecting toxicity information via ETAP outweighed both the delay and the cost of testing for most scenarios evaluated.

Overall, the results of the case study indicate that under the exposure scenarios and assumptions considered, the ETAP was more frequently preferred over the traditional toxicity testing and human health approach for more rapidly and cost effectively evaluating chemicals with no existing toxicity testing or human health data. The amount of time needed to conduct the toxicity testing and develop the human health assessment was particularly important when the risks were high as the delay in implementing regulatory action resulted in a large cost of delay.

## 2.6 BOARD OF SCIENTIFIC COUNSELORS (BOSC) SCIENTIFIC REVIEW OF ETAP DEVELOPMENT AND IMPLEMENTATION

The review of the ETAP methods by the EPA BOSC is being performed in close coordination with a separate review of the VOI case study comparing the short-term in vivo transcriptomic study and ETAP with the traditional chronic rodent bioassay and human health assessment process. The series of white papers are intended to be complementary and cover not only the scientific support for the proposed toxicity test and assessment product, but also the socioeconomic rationale.

For the ETAP, the review package to support the development and implementation of the assessment consists of two main documents. The first document (this one) is focused on the scientific studies and analyses supporting development of transcriptomic PODs for ETAP. Herein, the document is organized to provide the following information:

- A review of the relevant published literature that supports development of transcriptomic PODs and their concordance with apical toxicological responses across a broad range of exposure routes, exposure durations, physicochemical properties, toxicokinetic half-lives, tissues, chemical classes, and technology platforms.
- Development of transcriptomic PODs for ETAP including study design and transcriptomic platform-specific refinement of the transcriptomic dose response methods based on:
  ○ concordance of the transcriptomic PODs with apical PODs from chronic, repeated dose toxicity studies;
  ○ inter-study variability of the transcriptomic PODs; and
  ○ family-wise error rates^13^.
- Expected range of concordance between the transcriptomic and apical PODs in the context of the inter-study variability in both chronic, repeated-dose toxicity studies and short-term transcriptomic studies.

The second document details the methods for developing an ETAP and its implementation (EPA 2024b). That document is organized to provide the following information:

- Standard methods for developing an ETAP including the detailed methods for the initial database searches, systematic evidence mapping, short-term in vivo transcriptomic studies, human equivalent dose conversion, derivation of TRVs, and reporting and review.
- Comparison of TRVs with available EPA Integrated Risk Information System (IRIS) and Provisional Peer Reviewed Toxicity Value (PPRTV) reference doses (RfDs).
- ETAP reporting template.

1 US EPA TSCA Inventory: https://www.epa.gov/tsca-inventory

2 Multimedia Monitoring Database: https://comptox.epa.gov/dashboard/chemical-lists/MMDBV1

3 Biosolids: https://comptox.epa.gov/dashboard/chemical-lists/BIOSOLIDS2022

4 Produced water exists in subsurface formations and is brought to the surface during oil and gas production: https://comptox.epa.gov/dashboard/chemical-lists/PRODWATER

5 Organization for Economic Cooperation and Development (OECD) global PFAS database: https://comptox.epa.gov/dashboard/chemical-lists/PFASOECD

6 TSCA subset of the blood exposome: https://comptox.epa.gov/dashboard/chemical-lists/BLOODTSCA The TSCA subset of the blood exposome was used to represent the non-pesticide exogenous chemicals among those detected.

7 US EPA TSCA Inventory: https://www.epa.gov/tsca-inventory

8 In human health risk assessment practice, a point-of-departure (POD) represents the dose-response point that marks the beginning of a low-dose extrapolation. This point can be the lower bound on dose for an estimated incidence or a change in response level from a dose-response model (e.g., Benchmark Dose; BMD), or a No Observable Adverse Effect Level (NOAEL) or Lowest Observable Adverse Effect Level (LOAEL) for an observed incidence, or change in level of response. For BMD values, this is typically the BMD lower confidence bound (BMDL).

9 EPA Federal Insecticide, Fungicide, and Rodenticide Act (FIFRA) Science Advisory Panel White Paper: https://www.regulations.gov/document/EPA-HQ-OPP-2011-0284-0006

10 An apical endpoint is an observable outcome in a whole organism, such as a clinical sign or pathologic state, that is indicative of a disease state that can result from exposure to a toxicant (NASEM 2007). In this document, apical endpoints also include other phenotypic responses (e.g., organ and body weight changes) that are commonly used as critical effects in chemical risk assessment.

11 In this document, the transcriptomic POD is defined as the transcriptomic BMDL, which is calculated at the level of a gene set. Some studies in the review section may have defined the transcriptomic POD in other ways and these differences are noted, where evident.

12 Total benefits over the twenty-year time horizon for which the costs were calculated. To put these numbers in perspective, as an example, preventing a chronic health condition (costing $10,000 per year) among 330,000 people (approximately 1/10th of 1% of the US population) would provide a benefit of $66B over a 20-year time horizon.

13 Family-wise error rate refers to the probability of at least one Type I error (defined as rejecting the null hypothesis, given that it is true).