# 6 APPENDIX

## 6.1 SOURCE AND CALCULATION OF THE CHRONIC APICAL BMD AND BMDL VALUES

Apical BMD and BMDL values were obtained from the original Gwinn et al. publication (Gwinn et al. 2020) for twelve of the fourteen chemicals analyzed. For the remaining two chemicals, tris(2-chloroisopropyl) phosphate and di(2-ethylhexyl) phthalate, the histopathological results, feed, and body weight data for the male rat were extracted from the supplemental tables posted for peer review^28^ and the technical report (NTP 2021). The BMD modeling was performed on the dichotomous cancer and non-cancer histopathological data using Benchmark Dose Modeling Software (BMDS) version 3.201. The doses were adjusted for study specific feed consumption and body weights. The incidence rates were poly 3 adjusted using values from the supplemental tables. A standard benchmark response (BMR) of 10% extra risk was used for all datasets. The following BMD models were fit to the data: Dichotomous Hill, Gamma, Log-Logistic, Weibull, Logistic, Log-Probit, Probit, Multi-stage 1°, Multi-stage 2°, Multi-stage 3°, and Multi-stage 4°. Per the default recommendations in the BMDS software, the Dichotomous Hill, Gamma, Log-Logistic, Multi-stage, and Weibull models were restricted. Selection of BMDs were based on the recommendation procedures described in the EPA BMD Technical Guidance (EPA 2012).

### 6.1.1 TRIS(2-CHLOROISOPROPYL) PHOSPHATE

The daily doses from the feeding study were calculated based on the average food consumption and body weights across all 102 weeks of the study. The average daily dose was 164.4, 339.7, 724.9, and 1433.8 mg/kg-day for the 2500, 5000, 10000, and 20000 ppm feed concentrations, respectively. For non-neoplastic endpoints, lung granulomatous focal inflammation was selected as the non-neoplastic endpoint due to the fact that there was a significant increase at the 725 and 1433.8 mg/kg-day doses (poly 3 test), and it had the lowest BMD. The incidence and poly-3 adjusted animal numbers are provided in Table 6-1.

Table 6-1 Daily dose, incidence, and poly 3 adjusted rates for lung granulomatous focal inflammation in the male rat exposed to tris(2-chloroisopropyl) phosphate for 102 weeks

Daily Dose (mg/kg-day) | Number of Animals Based on Poly 3 Adjustment for Intercurrent Mortality | Incidence
0 | 39.93 | 7
164 | 43.68 | 14
340 | 46.13 | 11
725 | 44.51 | 19
1434 | 47.08 | 24

The recommended model by BMDS would not be preferred for this analysis (Table 6-2). Rather, the log-logistic model was chosen due to the lower AIC since the purpose was to get the best estimate of the BMD (i.e., central tendency) for comparing the concordance of the transcriptional and apical BMD values and not necessarily the “lowest BMDL” for a chemical assessment. The BMD, BMDL, and BMDU for lung granulomatous focal inflammation were 239.7, 140.7, and 834.4 mg/kg-day, respectively.

Table 6-2 BMD modeling output for lung granulomatous focal inflammation in the male rat

Model | BMD (mg/kg-day) | BMDL (mg/kg-day) | BMDU (mg/kg-day) | P Value | AIC | BMDS Recommendation
Dichotomous Hill | 223.6 | 58.8 | 743.2 | 0.374 | 296.07 | Viable - Recommended
Gamma | 303.1 | 203.9 | 768.5 | 0.535 | 294.27 | Viable - Alternate
Log-Logistic | 251.1 | 154.3 | 747.5 | 0.570 | 294.10 | Viable - Alternate
Multistage Degree 4 | 303.1 | 203.9 | 798.8 | 0.535 | 294.27 | Viable - Alternate
Multistage Degree 3 | 303.1 | 203.9 | 787.9 | 0.535 | 294.27 | Viable - Alternate
Multistage Degree 2 | 303.1 | 203.9 | 768.1 | 0.535 | 294.27 | Viable - Alternate
Multistage Degree 1 | 303.0 | 203.9 | 546.5 | 0.535 | 294.27 | Viable - Alternate
Weibull | 303.1 | 203.9 | 771.6 | 0.535 | 294.27 | Viable - Alternate
Logistic | 451.0 | 350.6 | 684.6 | 0.414 | 294.99 | Viable - Alternate
Log-Probit | 174.9 | 9.3 | 742.7 | 0.380 | 296.08 | Questionable
Probit | 433.9 | 335.5 | 668.4 | 0.428 | 294.90 | Viable - Alternate

For the neoplastic lesions, malignant and benign tumors for all organs showed a significant increase at the 725 mg/kg-day dose (poly 3 test). However, the malignant and benign tumors (all organs) endpoint was not selected for modeling given the high rate in control animals. The lung granulomatous focal inflammation was chosen as the critical effect.

### 6.1.2 DI(2-ETHYLHEXYL) PHTHALATE

The NTP technical report identified pancreatic acinar adenoma or carcinoma (combined) in the postweaning-only study (Study 2) as the neoplasm in male rats with the lowest BMD. The average daily doses from the feeding study, incidence, and number of animals based on poly 3 adjustment for intercurrent mortality were listed in the NTP technical report. The doses, incidence, and poly 3 adjusted animal numbers are listed in Table 6-3.

Table 6-3 Daily dose, incidence, and poly 3 adjusted rates pancreatic acinar adenoma or carcinoma (combined) in the male rat exposed to di(2-ethylhexyl) phthalate

Daily Dose (mg/kg-day) | Number of Animals Based on Poly 3 Adjustment for Intercurrent Mortality | Tumor Incidence
0 | 41.41 | 1
17 | 44.68 | 5
54 | 46.66 | 5
170 | 46.1 | 23
602 | 47.28 | 33

The log-logistic model was identified as the recommended model as it had the lowest AIC and a fit p-value > 0.1. The BMD, BMDL, and BMDU were 31.2, 20.3, and 63.1 mg/kg-day, respectively. Although the EPA typically uses linear multistage models for tumor dose response analysis, the fit p-values for the multi-stage models were all < 0.1 resulting in questionable fits to the data. If a multi-stage model was used, the first-degree model would be the best candidate since the b2 for the second-degree model was bounded. The BMD, BMDL, and BMDU for the first-degree linear multi-stage model were 44.7, 35.0, and 61.1 mg/kg-day, respectively. Given that the log-logistic model resulted in lower BMD and BMDL values, had a lower AIC, and a fit p-value > 0.1, it was selected as the preferred model. The details of the models are provided in Table 6-4.

Table 6-4 BMD modeling output for pancreatic acinar adenoma or carcinoma (combined) in the male rat

Model | BMD (mg/kg-day) | BMDL (mg/kg-day) | BMDU (mg/kg-day) | P Value | AIC | BMDS Recommendation
Dichotomous Hill | 71.0 | 20.7 | 150.4 | 0.110 | 205.06 | Viable - Alternate
Gamma | 44.7 | 35.0 | 68.1 | 0.069 | 205.29 | Questionable
Log-Logistic | 31.2 | 20.3 | 63.1 | 0.131 | 204.63 | Viable - Recommended
Multistage Degree 4 | 44.7 | 35.0 | 61.1 | 0.069 | 205.29 | Questionable
Multistage Degree 3 | 44.7 | 35.0 | 61.1 | 0.069 | 205.29 | Questionable
Multistage Degree 2 | 44.7 | 35.0 | 61.1 | 0.069 | 205.29 | Questionable
Multistage Degree 1 | 44.7 | 35.0 | 59.1 | 0.069 | 205.29 | Questionable
Weibull | 44.7 | 35.0 | 66.0 | 0.069 | 205.29 | Questionable
Logistic | 122.5 | 100.6 | 149.2 | 0.000 | 218.56 | Questionable
Log-Probit | 32.8 | 15.5 | 70.1 | 0.112 | 204.93 | Viable - Alternate
Probit | 115.8 | 96.9 | 139.4 | 0.000 | 217.55 | Questionable

A BMD analysis of non-neoplastic lesions in the male rat for Study 1 and 2 was performed, but no BMDs (i.e., central tendency; not the corresponding BMDL) were identified that were lower than the pancreatic acinar adenoma or carcinoma (combined) when the log-logistic model was utilized. The pancreatic acinar adenoma or carcinoma (combined) was chosen as the critical effect.

## 6.2 SEQUENCE ALIGNMENT, NORMALIZATION AND QUALITY CONTROL METHODS FOR RE-ANALYSIS OF THE NTP TRANSCRIPTOMIC STUDIES

The two NTP publications possessed transcriptomic measurements on a total of 1450 individual liver and kidney samples from 23 distinct studies conducted at NTP (Gwinn et al. 2020)(https://doi.org/10.22427/NTP-DATA-002-00099-0001-000-1). The transcriptomic measurements were performed using the BioSpyder TempO-Seq rat S1500+ platform. The raw sequencing reads (FASTQ files) were aligned to known probe sequences to compute a matrix of read counts for each probe in each sample, as described previously (Harrill et al. 2021a). Initial quality checks were performed post-alignment to identify samples with insufficient sequencing depth or input RNA to yield reliable results. Each FASTQ file was aligned to the TempO-Seq probe manifest using HISAT2 (Kim et al. 2015; Kim et al. 2019). The alignment results were then imported directly into SAMtools (Li et al. 2009) to compute probe-level counts for each individual FASTQ file. Samples were examined for the following quality statistics described previously (Harrill et al. 2021a) and those not meeting minimum quality standards were removed from the analysis:

- Samples with total uniquely aligned reads fewer than 10% of the median read depth were removed.
- Samples with < 50% of sequenced reads uniquely aligned to known probes were removed.
- NCov_5_ was computed as the total # of probes with at least 5 reads in each sample. This quality statistic is known to vary by cell type/source tissue (Harrill et al. 2021a). Liver samples with NCov_5_ < 1,400 and Kidney samples with NCov_5_ < 1,600 were removed.
- N_80_ was computed as the minimum number of probes that capture 80% of total mapped reads in the sample. No specific threshold for this value was set, but this quality statistic was considered when removing outliers, see below.

Of the 1450 total samples, 6 individual samples (0.4 %) were removed from further analysis based on the QC criteria above (Table 6-5). All removed samples had < 50% of sequenced reads uniquely aligned to known probe sequences.

Table 6-5 Samples removed based on QC metrics

Tissue | Animal ID | Chemical^a^ | Dose Group | QC Issue
Kidney | 105R | DE71 | 0.38 mg/kg-day | < 50% reads aligned
Kidney | 114R | DE71 | 1.5 mg/kg-day | < 50% reads aligned
Kidney | 116R | DE71 | 1.5 mg/kg-day | < 50% reads aligned
Kidney | 118R | DE71 | 3 mg/kg-day | < 50% reads aligned
Kidney | 127 | DE71 | 50 mg/kg-day | < 50% reads aligned
Kidney | 2823 | BDCA | 20 mg/kg-day | < 50% reads aligned

a DE-71, Pentabromodiphenyl ether; BDCA, Bromodichloroacetic acid.

Prior to performing downstream gene expression analysis across samples, TempO-seq probe counts for each sample were normalized to adjust for differences in sequencing depth. For each set of samples to be used for dose response modeling (i.e., each tissue for each test chemical), raw probe counts for all samples (including matched controls) were normalized within each sample as follows:

- All probes with a mean read count < 5 were removed, as these probes/genes lack sufficient signal for reliable analysis.
- Each remaining probe was normalized to Counts Per Million (CPM) = probe count * 1,000,000 / sum of all remaining probe counts in sample
- CPM values were transformed to log_2_ scale with added pseudo-count of 1 to prevent taking log of zero counts and ensuring a positive value for dose response modeling.

To identify potential outlier samples, a principal component analysis (PCA) was performed on subsets of samples corresponding to either: 1) all samples corresponding to same chemical and tissue, including matched vehicle controls (“treatment PCA”); and 2) all available vehicle controls corresponding to the same tissue (“vehicle PCA”). Samples not meeting the sequencing quality metrics described above (e.g., < 50% of uniquely aligned reads) were excluded prior to PCA analysis. Outlier samples were identified based on the following considerations:

- Individual samples separated from all remaining samples on either principal component #1 (PC1) or principal component #2 (PC2) by >2x the span of all other samples on the corresponding PC were considered strong outliers and removed from further analysis.
- Individual samples separated by <2x the range of all other samples were considered moderate outliers, and additional exclusion criteria were considered:
  ○ Vehicle samples that appear as moderate outliers on both a treatment PCA and vehicle PCA were excluded unless multiple controls from the same group appeared as outliers.
  ○ Moderate outlier samples with lower quality than corresponding tissue samples by one or more sequencing quality metrics (e.g., percentage of uniquely mapped reads) were excluded.
  ○ Samples that appear as moderate outliers in both PC1 and PC2 compared with other remaining samples were excluded.
  ○ Moderate outlier samples, where distance from all corresponding replicates or similar dose groups is greater than the pairwise distances between all other replicates of the same or similar doses, were excluded.

When multiple outlier samples were present on the same PCA, they were only removed if each outlier sample corresponded to a different dose group, as these are unlikely to represent any reproducible dose-dependent effect. A total of 21 samples (1 %) were removed as outliers (Table 6-6).

Table 6-6 Outlier samples removed based on PCA of samples grouped by chemical and tissue

Tissue | Animal ID | Chemical^a^ | Dose Group
Kidney | 304R | TCAB | Vehicle
Kidney | 810 | TCPP | 37.5 mg/kg-day
Kidney | 818 | TCPP | 150 mg/kg-day
Kidney | 822 | TCPP | 300 mg/kg-day
Liver | 1007 | PFOA | 0.156 mg/kg-day
Liver | 1012 | PFOA | 0.3125 mg/kg-day
Liver | 1015 | PFOA | 0.625 mg/kg-day
Liver | 1020 | PFOA | 1.25 mg/kg-day
Liver | 1021 | PFOA | 2.5 mg/kg-day
Liver | 1311 | Methyl eugenol | 9.25 mg/kg-day
Kidney | 1318 | Methyl eugenol | 37 mg/kg-day
Kidney | 1419 | Coumarin | 25 mg/kg-day
Liver | 1432 | Coumarin | 200 mg/kg-day
Liver | 1630 | BDCA | 80 mg/kg-day
Kidney | 1632 | BDCA | 80 mg/kg-day
Liver | 1716 | α,β-Thujone | 6.25 mg/kg-day
Liver | 1801 | Furan | Vehicle
Liver | 1808 | Furan | 0.125 mg/kg-day
Liver | 1824 | Furan | 2 mg/kg-day
Kidney | 2226 | Furan | 4 mg/kg-day
Liver | 2816 | BDCA | 5 mg/kg-day

a TCAB, 3,3’,4,4’-Tetrachloroazobenzene; TCPP, Tris(2-chloroisopropyl) phosphate; PFOA, Perfluorooctanoic acid; BDCA, Bromodichloroacetic acid.

## 6.3 SEARCH STRATEGY FOR LITERATURE REVIEW

The following process was used to identify and screen articles for inclusion in the transcriptomic dose response sections of the literature review.

1. An initial list of expertly curated papers was assembled that focused on transcriptomic dose response analysis with application of benchmark dose methods (Table 6-7).
2. The articles were imported into Abstract Sifter^29^ (Version 7)(Baker et al. 2017).
3. After importing, the ‘Like articles’ option was selected to identify similar articles^30^. The initial search also included articles that used other molecular measures besides gene expression (e.g., microRNA) and exposures that used nanoparticles; however, these articles were subsequently excluded due to the focus of the ETAP on mRNA and chemicals, respectively.
4. All ‘Like articles’ were imported into Abstract Sifter and duplicates removed to result in 874 articles.
5. The TermMap function in Abstract Sifter was used to sort the papers from high to low. The terms used are listed in Table 6-8.
6. Titles and abstracts were scanned for relevance by two reviewers. If any conflicts were identified, consensus was reached through discussion. Only in vivo studies using mice or rats were retained as likely relevant. A total of 81 papers were identified (Table 6-9).
7. The 81 papers identified as potentially relevant (see Table 6-9) were reviewed in greater depth. The inclusion criteria were as follows: mouse or rat, at least 3 dose levels, BMD modeling of gene expression data obtained after 1 to 90 days of exposure, and comparison to apical effects Some of the articles identified as likely relevant were methods papers and some were re-analysis of data generated from different, earlier studies. Of the 81 likely relevant articles reviewed, there was data from 29 independent studies.
8. A separate search of NTP reports was performed to identify additional studies. The search identified 4 additional studies/reports for the literature review (NIEHS 2022a, b, c, d).
9. For the concordance analysis and scatter plots (Figures 3-1 to 3-3), only studies reporting a transcriptomic BMD (obtained after 1 to 90 days exposure) and two-year, chronic apical BMD. For those papers that reanalyzed data, the approach most similar to those proposed in the ETAP methods (e.g., the gene set with the lowest median BMD value) was used resulting in 21 articles contributing to the concordance analysis and scatter plots. The specific articles used for each figure are provided in Tables 6-10, 6-11, and 6-12 and cited in the figure legends.

Table 6-7 Initial articles used as the base query for the literature review

PMID | Year | Title | Log | Log time | Number of Like Articles
18499655 | 2008 | Genomic signatures and dose-dependent transitions in nasal epithelial responses to inhaled formaldehyde in the rat. | Articles like 18499655 | 8/19/2022 16:11 | 145
20801182 | 2010 | Toxicogenomics and cancer risk assessment: a framework for key event analysis and dose response assessment for nongenotoxic carcinogens. | Articles like 20801182 | 8/19/2022 16:10 | 200
20884683 | 2010 | Formaldehyde: integrating dosimetry, cytotoxicity, and genomics to understand dose-dependent transitions for an endogenous compound. | Articles like 20884683 | 8/19/2022 15:05 | 157
21097997 | 2011 | Application of transcriptional benchmark dose values in quantitative cancer and noncancer risk assessment. | Articles like 21097997 | 8/19/2022 15:04 | 144
21795629 | 2011 | Concentration- and time-dependent genomic changes in the mouse urinary bladder following exposure to arsenate in drinking water for up to 12 weeks. | Articles like 21795629 | 8/19/2022 15:01 | 86
22305970 | 2012 | Integrating pathway-based transcriptomic data into quantitative chemical risk assessment: a five chemical case study. | Articles like 22305970 | 8/19/2022 15:01 | 73
23125180 | 2013 | Cross-species transcriptomic analysis of mouse and rat lung exposed to chloroprene. | Articles like 23125180 | 8/19/2022 15:00 | 90
23596260 | 2013 | Temporal concordance between apical and transcriptional points of departure for chemical risk assessment. | Articles like 23596260 | 8/19/2022 14:59 | 115
23970803 | 2013 | Concordance of transcriptional and apical benchmark dose levels for conazole-induced liver effects in mice. | Articles like 23970803 | 8/19/2022 14:59 | 114
24183702 | 2014 | Case study on the utility of hepatic global gene expression profiling in the risk assessment of the carcinogen furan. | Articles like 24183702 | 8/19/2022 14:52 | 163
24449422 | 2014 | Dose response modeling of early molecular and cellular key events in the CAR-mediated hepatocarcinogenesis pathway. | Articles like 24449422 | 8/19/2022 14:51 | 109
24952340 | 2014 | Time- and concentration-dependent genomic responses of the rat airway to inhaled nickel subsulfide. | Articles like 24952340 | 8/19/2022 14:50 | 102
24976557 | 2014 | Transcriptional responses in the rat nasal epithelium following subchronic inhalation of naphthalene vapor. | Articles like 24976557 | 8/19/2022 14:49 | 137
25605026 | 2015 | Comparison of toxicogenomics and traditional approaches to inform mode of action and points of departure in human health risk assessment of benzo[a]pyrene in drinking water. | Articles like 25605026 | 8/19/2022 14:49 | 186
26194646 | 2016 | Toxicogenomic assessment of liver responses following subchronic exposure to furan in Fischer F344 rats. | Articles like 26194646 | 8/19/2022 14:48 | 133
26519955 | 2016 | Dose and Effect Thresholds for Early Key Events in a PPARα-Mediated Mode of Action. | Articles like 26519955 | 8/19/2022 14:47 | 94
26979667 | 2016 | Nano-risk Science: application of toxicogenomics in an adverse outcome pathway framework for risk assessment of multi-walled carbon nanotubes. | Articles like 26979667 | 8/19/2022 8:55 | 200
27638505 | 2017 | Hepatic transcriptomic alterations for N,N-dimethyl-p-toluidine (DMPT) and p-toluidine after 5-day exposure in rats. | Articles like 27638505 | 8/19/2022 8:55 | 114
27858113 | 2017 | A framework for the use of single-chemical transcriptomics data in predicting the hazards associated with complex mixtures of polycyclic aromatic hydrocarbons. | Articles like 27858113 | 8/19/2022 8:54 | 132
27859739 | 2016 | Transcriptomic responses in the oral cavity of F344 rats and B6C3F1 mice following exposure to Cr(VI): Implications for risk assessment. | Articles like 27859739 | 8/19/2022 8:53 | 129
27928627 | 2017 | Recommended approaches in the application of toxicogenomics to derive points of departure for chemical risk assessment. | Articles like 27928627 | 8/19/2022 8:53 | 138
28123101 | 2017 | Editor’s Highlight: Application of Gene Set Enrichment Analysis for Identification of Chemically Induced, Biologically Relevant Transcriptomic Networks and Potential Utilization in Human Health Risk Assessment. | Articles like 28123101 | 8/19/2022 8:52 | 93
28403741 | 2017 | Impact of Acrylamide on Calcium Signaling and Cytoskeletal Filaments in Testes from F344 Rat. | Articles like 28403741 | 8/19/2022 8:50 | 76
28606764 | 2017 | Transcriptional profiling of male F344 rats suggests the involvement of calcium signaling in the mode of action of acrylamide-induced thyroid cancer. | Articles like 28606764 | 8/19/2022 8:49 | 77
28717101 | 2017 | Mechanism-based risk assessment strategy for drug-induced cholestasis using the transcriptional benchmark dose derived by toxicogenomics. | Articles like 28717101 | 8/19/2022 8:48 | 75
28927277 | 2017 | Benchmark Dose Modeling Estimates of the Concentrations of Inorganic Arsenic That Induce Changes to the Neonatal Transcriptome, Proteome, and Epigenome in a Pregnancy Cohort. | Articles like 28927277 | 8/19/2022 8:47 | 98
28973375 | 2017 | Editor’s Highlight: Comparative Dose response Analysis of Liver and Kidney Transcriptomic Effects of Trichloroethylene and Tetrachloroethylene in B6C3F1 Mouse. | Articles like 28973375 | 8/19/2022 8:47 | 175
30589522 | 2018 | NTP Research Report on In Vivo Repeat Dose Biological Potency Study of Triphenyl Phosphate (CAS No. 115-86-6) in Male Sprague Dawley Rats (Hsd: Sprague Dawley SD) (Gavage Studies): Research Report 8 | Articles like 30589522 | 8/19/2022 8:46 | 103
30594549 | 2019 | Hepatic transcriptional dose response analysis of male and female Fischer rats exposed to hexabromocyclododecane. | Articles like 30594549 | 8/19/2022 8:46 | 118
32268158 | 2020 | Short-term toxicogenomics as an alternative approach to chronic in vivo studies for derivation of points of departure: A case study in the rat with a triazole fungicide. | Articles like 32268158 | 8/19/2022 8:44 | 117
32384157 | 2020 | A Rat Liver Transcriptomic Point of Departure Predicts a Prospective Liver or Non-liver Apical Point of Departure. | Articles like 32384157 | 8/19/2022 8:43 | 106
32492150 | 2020 | Evaluation of 5-day In Vivo Rat Liver and Kidney With High-throughput Transcriptomics for Estimating Benchmark Doses of Apical Outcomes. | Articles like 32492150 | 8/19/2022 8:39 | 112
32642447 | 2020 | Early microRNA indicators of PPARα pathway activation in the liver. | Articles like 32642447 | 8/19/2022 8:38 | 144
32679240 | 2020 | Comparative toxicity and liver transcriptomics of legacy and emerging brominated flame retardants following 5-day exposure in the rat. | Articles like 32679240 | 8/19/2022 8:37 | 121
32904430 | 2020 | Transcriptomic data from the rat liver after five days of exposure to legacy or emerging brominated flame retardants. | Articles like 32904430 | 8/19/2022 8:35 | 97
33217531 | 2021 | A rat subchronic study transcriptional point of departure estimates a carcinogenicity study apical point of departure. | Articles like 33217531 | 8/19/2022 8:33 | 107
35194992 | 2022 | Integration of Toxicogenomics and Physiologically Based Pharmacokinetic Modeling in Human Health Risk Assessment of Perfluorooctane Sulfonate. | Articles like 35194992 | 8/19/2022 8:32 | 109
35537365 | 2022 | Harmonization of transcriptomic and methylomic analysis in environmental epidemiology studies for potential application in chemical risk assessment. | Articles like 35537365 | 8/19/2022 8:30 | 103
35596682 | 2022 | A microRNA or messenger RNA point of departure estimates an apical endpoint point of departure in a rat developmental toxicity model. | Articles like 35596682 | 8/19/2022 8:29 | 93
24194394 | 2014 | Comparison of microarrays and RNA-seq for gene expression analyses of dose response experiments | Articles like 24194394 | 8/19/2022 14:52 | 200
26313361 | 2015 | Impact of Genomics Platform and Statistical Filtering on Transcriptional Benchmark Doses (BMD) and Multiple Approaches for Selection of Chemical Point of Departure (PoD) | Articles like 26313361 | 8/19/2022 14:48 | 171

Table 6-8 TermMap functions and results from Pubmed ‘like articles’ query

Map to this: | When you see this: | Article Count | Boost by Term
Benchmark dose | benchmark dose | 170 | 3
Benchmark dose | dose response | 33 | 3
Benchmark dose | BMD | 147 | 1
Transcript | genomic | 256 | 2
Transcript | transcript | 382 | 1
Transcript | gene | 744 | 1
Transcript | transcriptome | 208 | 2
Risk | risk | 310 | 1
Risk | risk assessment | 256 | 2
Benchmark dose total: | Total: | 195
Transcript total: | Total: | 753
Risk total: | Total: | 310

Table 6-9 Likely relevant articles identified following initial screening

| TermMap Terms
PMID | Benchmark Dose | Risk | Transcript | Score | Year | Title
17449896 | 13 | 14 | 5 | 32 | 2007 | A method to integrate benchmark dose estimates with genomic data to assess the functional effects of chemical exposure.
20884683 | 9 | 12 | 10 | 31 | 2010 | Formaldehyde: integrating dosimetry, cytotoxicity, and genomics to understand dose-dependent transitions for an endogenous compound.
21097997 | 12 | 15 | 12 | 39 | 2011 | Application of transcriptional benchmark dose values in quantitative cancer and noncancer risk assessment.
22305970 | 11 | 16 | 18 | 45 | 2012 | Integrating pathway-based transcriptomic data into quantitative chemical risk assessment: a five chemical case study.
23596260 | 15 | 16 | 23 | 54 | 2013 | Temporal concordance between apical and transcriptional points of departure for chemical risk assessment.
23970803 | 18 | 13 | 11 | 42 | 2013 | Concordance of transcriptional and apical benchmark dose levels for conazole-induced liver effects in mice.
20849870 | 11 | 18 | 10 | 39 | 2013 | Use of genomic data in risk assessment case study: I. Evaluation of the dibutyl phthalate male reproductive development toxicity data set.
23146762 | 11 | 18 | 10 | 39 | 2013 | Gene expression profiling to identify potentially relevant disease outcomes and support human health risk assessment for carbon black nanoparticle exposure.
24194394 | 15 | 12 | 19 | 46 | 2014 | Comparison of microarrays and RNA-seq for gene expression analyses of dose response experiments.
24183702 | 13 | 16 | 11 | 40 | 2014 | Case study on the utility of hepatic global gene expression profiling in the risk assessment of the carcinogen furan.
24976557 | 11 | 11 | 12 | 34 | 2014 | Transcriptional responses in the rat nasal epithelium following subchronic inhalation of naphthalene vapor.
24952340 | 11 | 11 | 10 | 32 | 2014 | Time- and concentration-dependent genomic responses of the rat airway to inhaled nickel subsulfide.
24449422 | 10 | 5 | 14 | 29 | 2014 | Dose response modeling of early molecular and cellular key events in the CAR-mediated hepatocarcinogenesis pathway.
26671443 | 12 | 14 | 20 | 46 | 2016 | BMDExpress Data Viewer - a visualization tool to analyze BMDExpress datasets.
27601323 | 12 | 15 | 13 | 40 | 2016 | Transcriptional benchmark dose modeling: Exploring how advances in chemical risk assessment may be applied to the radiation field.
27859739 | 9 | 13 | 18 | 40 | 2016 | Transcriptomic responses in the oral cavity of F344 rats and B6C3F1 mice following exposure to Cr(VI): Implications for risk assessment.
26377693 | 9 | 11 | 19 | 39 | 2016 | Comparative transcriptomic analyses to scrutinize the assumption that genotoxic PAHs exert effects via a common mode of action.
26194646 | 12 | 0 | 21 | 33 | 2016 | Toxicogenomic assessment of liver responses following subchronic exposure to furan in Fischer F344 rats.
26496743 | 10 | 12 | 10 | 32 | 2016 | Transcriptional Profiling of Dibenzo[def,p]chrysene-induced Spleen Atrophy Provides Mechanistic Insights into its Immunotoxicity in MutaMouse.
27562560 | 14 | 0 | 18 | 32 | 2016 | Editor’s Highlight: Dose response Analysis of RNA-Seq Profiles in Archival Formalin-Fixed Paraffin-Embedded Samples.
28123101 | 11 | 15 | 22 | 48 | 2017 | Editor’s Highlight: Application of Gene Set Enrichment Analysis for Identification of Chemically Induced, Biologically Relevant Transcriptomic Networks and Potential Utilization in Human Health Risk Assessment.
27638505 | 12 | 12 | 20 | 44 | 2017 | Hepatic transcriptomic alterations for N,N-dimethyl-p-toluidine (DMPT) and p-toluidine after 5-day exposure in rats.
28717101 | 12 | 14 | 11 | 37 | 2017 | Mechanism-based risk assessment strategy for drug-induced cholestasis using the transcriptional benchmark dose derived by toxicogenomics.
27858113 | 11 | 11 | 14 | 36 | 2017 | A framework for the use of single-chemical transcriptomics data in predicting the hazards associated with complex mixtures of polycyclic aromatic hydrocarbons.
28973375 | 0 | 12 | 21 | 33 | 2017 | Editor’s Highlight: Comparative Dose response Analysis of Liver and Kidney Transcriptomic Effects of Trichloroethylene and Tetrachloroethylene in B6C3F1 Mouse.
28927277 | 12 | 0 | 20 | 32 | 2017 | Benchmark Dose Modeling Estimates of the Concentrations of Inorganic Arsenic That Induce Changes to the Neonatal Transcriptome, Proteome, and Epigenome in a Pregnancy Cohort.
29475067 | 9 | 11 | 15 | 35 | 2018 | Transcriptional profiling of male CD-1 mouse lungs and Harderian glands supports the involvement of calcium signaling in acrylamide-induced tumors.
30321009 | 11 | 11 | 10 | 32 | 2018 | NTP Research Report on National Toxicology Program Approach to Genomic Dose response Modeling: Research Report 5
29329100 | 13 | 15 | 0 | 28 | 2018 | A Web-Based System for Bayesian Benchmark Dose Estimation.
30594549 | 12 | 12 | 22 | 46 | 2019 | Hepatic transcriptional dose response analysis of male and female Fischer rats exposed to hexabromocyclododecane.
30329029 | 2 | 11 | 21 | 34 | 2019 | BMDExpress 2: enhanced transcriptomic dose response analysis workflow.
32413060 | 15 | 13 | 17 | 45 | 2020 | The sensitivity of transcriptomics BMD modeling to the methods used for microarray data normalization.
32268158 | 9 | 12 | 11 | 32 | 2020 | Short-term toxicogenomics as an alternative approach to chronic in vivo studies for derivation of points of departure: A case study in the rat with a triazole fungicide.
31950985 | 12 | 0 | 19 | 31 | 2020 | BMDx: a graphical Shiny application to perform Benchmark Dose analysis for transcriptomics data.
32687419 | 13 | 13 | 18 | 44 | 2021 | Meta-analysis of transcriptomic datasets using benchmark dose modeling shows value in supporting radiation risk assessment.
32761065 | 13 | 0 | 17 | 30 | 2021 | FastBMD: an online tool for rapid benchmark dose response analysis of transcriptomics data.
35537365 | 11 | 15 | 23 | 49 | 2022 | Harmonization of transcriptomic and methylomic analysis in environmental epidemiology studies for potential application in chemical risk assessment.
35939396 | 13 | 12 | 11 | 36 | 2022 | Evaluating the Influences of Confounding Variables on Benchmark Dose using a Case Study in the Field of Ionizing Radiation.
35151117 | 13 | 12 | 11 | 36 | 2022 | A computational system for Bayesian benchmark dose estimation of genomic data in BBMD.
35194992 | 11 | 17 | 5 | 33 | 2022 | Integration of Toxicogenomics and Physiologically Based Pharmacokinetic Modeling in Human Health Risk Assessment of Perfluorooctane Sulfonate.
23125180 | 11 | 0 | 17 | 28 | 2013 | Cross-species transcriptomic analysis of mouse and rat lung exposed to chloroprene.
28606764 | 9 | 11 | 8 | 28 | 2017 | Transcriptional profiling of male F344 rats suggests the involvement of calcium signaling in the mode of action of acrylamide-induced thyroid cancer.
33362981 | 13 | 12 | 0 | 25 | 2020 | bmd: an R package for benchmark dose estimation.
18441342 | 9 | 13 | 5 | 27 | 2008 | Automated quantitative dose response modeling and point of departure determination for large toxicogenomic and high-throughput screening data sets.
21795629 | 11 | 11 | 5 | 27 | 2011 | Concentration- and time-dependent genomic changes in the mouse urinary bladder following exposure to arsenate in drinking water for up to 12 weeks.
32642447 | 16 | 0 | 9 | 25 | 2020 | Early microRNA indicators of PPARα pathway activation in the liver.
23831126 | 9 | 11 | 5 | 25 | 2013 | Gene batteries and synexpression groups applied in a multivariate statistical approach to dose response analysis of toxicogenomic data.
17682005 | 0 | 12 | 11 | 23 | 2007 | Exposure to arsenic at levels found in U.S. drinking water modifies expression in the mouse lung.
17961223 | 13 | 0 | 11 | 24 | 2007 | BMDExpress: a software tool for the benchmark dose analyses of genomic data.
35939275 | 13 | 0 | 10 | 23 | 2022 | Benchmark dose modeling of transcriptional data: a systematic approach to identify best practices for study designs used in radiation research.
18499655 | 13 | 0 | 10 | 23 | 2008 | Genomic signatures and dose-dependent transitions in nasal epithelial responses to inhaled formaldehyde in the rat.
25554681 | 0 | 11 | 12 | 23 | 2015 | MWCNTs of different physicochemical properties cause similar inflammatory responses, but differences in transcriptional and histological markers of fibrosis in mouse lungs.
28495587 | 13 | 0 | 10 | 23 | 2017 | Dose response analysis of epigenetic, metabolic, and apical endpoints after short-term exposure to experimental hepatotoxicants.
30589522 | 12 | 0 | 10 | 22 | 2018 | NTP Research Report on In Vivo Repeat Dose Biological Potency Study of Triphenyl Phosphate (CAS No. 115-86-6) in Male Sprague Dawley Rats (Hsd: Sprague Dawley SD) (Gavage Studies): Research Report 8
26519955 | 12 | 0 | 10 | 22 | 2016 | Dose and Effect Thresholds for Early Key Events in a PPARα-Mediated Mode of Action.
31202941 | 0 | 13 | 8 | 21 | 2019 | Hexabromocyclododecane (HBCD): A case study applying tiered testing for human health risk assessment.
32904430 | 10 | 0 | 12 | 22 | 2020 | Transcriptomic data from the rat liver after five days of exposure to legacy or emerging brominated flame retardants.
18549499 | 0 | 11 | 10 | 21 | 2008 | Sources of variation in baseline gene expression levels from toxicogenomics study control animals across multiple laboratories.
20957103 | 0 | 5 | 16 | 21 | 2010 | Practical application of toxicogenomics for profiling toxicant-induced biological perturbations.
29945496 | 0 | 5 | 16 | 21 | 2018 | Pathogenesis of Renal Injury and Gene Expression Changes in the Male CD-1 Mouse Associated with Exposure to Empagliflozin.
32679240 | 0 | 0 | 20 | 20 | 2020 | Comparative toxicity and liver transcriptomics of legacy and emerging brominated flame retardants following 5-day exposure in the rat.
25958198 | 4 | 0 | 15 | 19 | 2015 | RNA-Seq versus oligonucleotide array assessment of dose-dependent TCDD-elicited hepatic gene expression in mice.
27928627 | 11 | 16 | 23 | 50 | 2017 | Recommended approaches in the application of toxicogenomics to derive points of departure for chemical risk assessment.
17118914 | 0 | 0 | 16 | 16 | 2006 | Microarray-based compendium of hepatic gene expression profiles for prototypical ADME gene-inducing compounds in rats and mice in vivo.
32258091 | 12 | 0 | 5 | 17 | 2020 | Aristolochic Acid-Induced Genotoxicity and Toxicogenomic Changes in Rodents.
35083394 | 12 | 0 | 5 | 17 | 2022 | ALOHA: Aggregated local extrema splines for high-throughput dose response analysis.
35176998 | 0 | 0 | 16 | 16 | 2022 | Evaluating the cytotoxicity and pathogenicity of multi-walled carbon nanotube through weighted gene co-expression network analysis: a nanotoxicogenomics study.
15056800 | 0 | 0 | 14 | 14 | 2004 | Bromobenzene-induced hepatotoxicity at the transcriptome level.
26979667 | 12 | 15 | 13 | 40 | 2016 | Nano-risk Science: application of toxicogenomics in an adverse outcome pathway framework for risk assessment of multi-walled carbon nanotubes.
28403741 | 11 | 0 | 2 | 13 | 2017 | Impact of Acrylamide on Calcium Signaling and Cytoskeletal Filaments in Testes from F344 Rat.
32492150 | 13 | 5 | 19 | 37 | 2020 | Evaluation of 5-day In Vivo Rat Liver and Kidney with High-throughput Transcriptomics for Estimating Benchmark Doses of Apical Outcomes.
33217531 | 12 | 13 | 17 | 42 | 2021 | A rat subchronic study transcriptional point of departure estimates a carcinogenicity study apical point of departure.
25605026 | 9 | 16 | 11 | 36 | 2015 | Comparison of toxicogenomics and traditional approaches to inform mode of action and points of departure in human health risk assessment of benzo[a]pyrene in drinking water.
32384157 | 11 | 13 | 20 | 44 | 2020 | A Rat Liver Transcriptomic Point of Departure Predicts a Prospective Liver or Non-liver Apical Point of Departure.
26313361 | 12 | 13 | 11 | 36 | 2015 | Impact of Genomics Platform and Statistical Filtering on Transcriptional Benchmark Doses (BMD) and Multiple Approaches for Selection of Chemical Point of Departure (PoD).
31881176 | 11 | 14 | 11 | 36 | 2020 | A toxicogenomic approach for the risk assessment of the food contaminant acetamide.
20801182 | 10 | 14 | 5 | 29 | 2010 | Toxicogenomics and cancer risk assessment: a framework for key event analysis and dose response assessment for nongenotoxic carcinogens.
15834898 | 0 | 0 | 7 | 7 | 2005 | Evaluation of the gene expression changes induced by 17-alpha-ethynyl estradiol in the immature uterus/ovaries of the rat using high density oligonucleotide arrays.
21624382 | 0 | 5 | 2 | 7 | 2011 | Multi-walled carbon nanotube-induced gene expression in the mouse lung: association with lung pathology.
35596682 | 2 | 11 | 11 | 24 | 2022 | A microRNA or messenger RNA point of departure estimates an apical endpoint point of departure in a rat developmental toxicity model.
32449777 | 2 | 0 | 16 | 18 | 2020 | TinderMIX: Time-dose integrated modelling of toxicogenomics data.
36518475 | 17 | 5 | 11 | 33 | 2022 | Case study: Targeted RNA-sequencing of aged formalin-fixed paraffin-embedded samples for understanding chemical mode of action.

Table 6-10 Rat and mouse transcriptomic BMD(L) values for lowest gene set from 1 to 90-day exposures and BMD(L) values for traditional non-cancer and cancer endpoints from rodent bioassays reported in literature search. The data used to create Figure 3-1

Chemical (CASRN) | Species and strain/ stock | Sex | Route | Gene Expression Timepoint (d) | Gene Expression Tissue | Lowest Transcriptomic BMD (BMDL) | Endpoint | Lowest Traditional Endpoint BMD (BMDL) | BMD(L) Units | Study PubMed ID
Paraformaldehyde (30525-89-4) | F344/NCrl rat | M | I | 1 | Nasal epithelium | 1.6 (1.1) | Nasal epithelium cell proliferation | 4.9 (3.8) | ppm | 17449896
Paraformaldehyde (30525-89-4) | F344/ CrlBR rat | M | I | 7 | Nasal epithelium | 3.7 (2.7) | Nasal epithelium cell proliferation | 4.9 (3.8) | ppm | 20884683
Paraformaldehyde (30525-89-4) | F344/ CrlBR rat | M | I | 28 | Nasal epithelium | 4.0 (2.7) | Nasal epithelium cell proliferation | 4.9 (3.8) | ppm | 20884683
Paraformaldehyde (30525-89-4) | F344/ CrlBR rat | M | I | 91 | Nasal epithelium | 2.7 (1.9) | Nasal epithelium cell proliferation | 4.9 (3.8) | ppm | 20884683
Fenofibrate (49562-28-9) | Rat | F | G | 2 | Liver | 4.7 (3.3) | Hepatocellular carcinoma | 57 (40) | mg/kg | 20801182
Methapyrilene (135-23-9) | Hsd:SD | M | G | 7 | Liver | 28.8 (11.2) | Hepatocellular carcinoma | 7.0 (4.0) | mg/kg | 20801182
1,4-Dichlorobenzene (106-46-7) | B6C3F1 mouse | F | G | 91 | Liver | 65 (38) | Liver adenoma and carcinoma | 218 (158) | mg/kg | 21097997
Methylene chloride (75-09-2) | B6C3F1 mouse | F | I | 91 | Lung | 1137 (694) | Lung adenoma and carcinoma | 791 (632) | mg/m^3^ | 21097997
Methylene chloride (75-09-2) | B6C3F1 mouse | F | I | 91 | Liver | 1265 (728) | Liver adenoma and carcinoma | 3544 (1931) | mg/m^3^ | 21097997
Naphthalene (91-20-3) | B6C3F1 mouse | F | I | 91 | Lung | 17 (10) | Lung adenoma and carcinoma | 120 (92) | mg/m^3^ | 21097997
Propylene glycol mono-t-butyl ether (57018-52-7) | B6C3F1 mouse | F | I | 91 | Liver | 677 (388) | Liver adenoma and carcinoma | 1774 (866) | mg/m^3^ | 21097997
1,2,3-trichloropropane (96-18-4) | B6C3F1 mouse | F | G | 91 | Liver | 7.4 (4.0) | Liver adenoma and carcinoma | 2.8 (1.3) | mg/kg | 21097997
β-Chloroprene (126-99-8) | B6C3F1/Crl mouse | F | I | 5 | Lung | 1.8 (1.1) | Time-to-lung tumor | 1.2 (0.88) | ppm | 23125180
β-Chloroprene (126-99-8) | B6C3F1/ Crl mouse | F | I | 15 | Lung | 5.9 (3.9) | Time-to-lung tumor | 1.2 (0.88) | ppm | 23125180
β-Chloroprene (126-99-8) | F344/NCrl rat | F | I | 5 | Lung | 38 (24) | Lung tumor | 102 (76) | ppm | 23125180
β-Chloroprene (126-99-8) | F344/NCrl rat | F | I | 15 | Lung | 13 (8.0) | Lung tumor | 102 (76) | ppm | 23125180
4,4′-Methylenebis (N,N-dimethyl) benzenamine (101-61-1) | F344 rat | F | F | 5 | Thyroid | 17 (13) | Thyroid follicular cell carcinoma and adenoma | 30 (22) | adjusted to mg/kg | 23596260
4,4′-Methylenebis (N,N-dimethyl) benzenamine (101-61-1) | F344 rat | F | F | 14 | Thyroid | 23 (14) | Thyroid follicular cell carcinoma and adenoma | 30 (22) | adjusted to mg/kg | 23596260
4,4′-Methylenebis (N,N-dimethyl) benzenamine (101-61-1) | F344 rat | F | F | 28 | Thyroid | 20 (12) | Thyroid follicular cell carcinoma and adenoma | 30 (22) | adjusted to mg/kg | 23596260
4,4′-Methylenebis (N,N-dimethyl) benzenamine (101-61-1) | F344 rat | F | F | 91 | Thyroid | 21 (12) | Thyroid follicular cell carcinoma and adenoma | 30 (22) | adjusted to mg/kg | 23596260
Hydrazobenzene (122-66-7) | F344 rat | M | F | 5 | Liver | 7.0 (4.2) | Hepatocellular carcinomas and neoplastic liver nodules | 3.0 (1.7) | adjusted to mg/kg | 23596260
Hydrazobenzene (122-66-7) | F344 rat | M | F | 14 | Liver | 7.8 (6.1) | Hepatocellular carcinomas and neoplastic liver nodules | 3.0 (1.7) | adjusted to mg/kg | 23596260
Hydrazobenzene (122-66-7) | F344 rat | M | F | 28 | Liver | 6.3 (4.0) | Hepatocellular carcinomas and neoplastic liver nodules | 3.0 (1.7) | adjusted to mg/kg | 23596260
Hydrazobenzene (122-66-7) | F344 rat | M | F | 91 | Liver | 3.6 (2.0) | Hepatocellular carcinomas and neoplastic liver nodules | 3.0 (1.7) | adjusted to mg/kg | 23596260
N-Nitrosodiphenylamine (86-30-6) | F344 rat | F | F | 5 | Bladder | 173 (130) | Transitional cell carcinoma of the bladder | 184 (138) | adjusted to mg/kg | 23596260
N-Nitrosodiphenylamine (86-30-6) | F344 rat | F | F | 14 | Bladder | 104 (66) | Transitional cell carcinoma of the bladder | 184 (138) | adjusted to mg/kg | 23596260
N-Nitrosodiphenylamine (86-30-6) | F344 rat | F | F | 28 | Bladder | 162 (124) | Transitional cell carcinoma of the bladder | 184 (138) | adjusted to mg/kg | 23596260
N-Nitrosodiphenylamine (86-30-6) | F344 rat | F | F | 91 | Bladder | 158 (122) | Transitional cell carcinoma of the bladder | 184 (138) | adjusted to mg/kg | 23596260
Cyproconazole (94361-06-5) | CD-1 mouse | M | F | 30 | Liver | NA (9.0) | Liver adenoma or carcinoma | NA (2.1) | adjusted to mg/kg | 23970803
Epoxiconazole (133855-98-8) | CD-1 mouse | M | F | 30 | Liver | NA (16) | Liver adenoma or carcinoma | NA (33) | adjusted to mg/kg | 23970803
Propiconazole (60207-90-1) | CD-1 mouse | M | F | 30 | Liver | NA (56) | Liver adenoma or carcinoma | NA (65) | adjusted to mg/kg | 23970803
Triadimefon (43121-43-3) | CD-1 mouse | M | F | 30 | Liver | NA (58) | Liver adenoma or carcinoma | NA (270) | adjusted to mg/kg | 23970803
Furan (110-00-9) | B3C6F1 mouse | F | G | 21 | Liver | 1.9 (1.4) | Hepatocellular adenoma | 2.3 (1.3) | mg/kg | 24183702
Benzo(a)pyrene (50-32-8) | B6C3F1 mouse | M | G | 3 | Liver | 0.3 (0.2) | Liver tumor | 1.8 (1.2) | mg/kg | 25605026
Benzo(a)pyrene (50-32-8) | Muta™ Mouse | M | G | 28 | Liver | 25 (5.3) | Liver tumor | 1.8 (1.2) | mg/kg | 25605026
Furan (110-00-9) | F344 rat | M | G | 90 | Liver | 0.08 (0.05) | Hepatocellular adenoma or carcinoma | 1.8 (1.3) | mg/kg | 26194646
Furan (110-00-9) | F344 rat | F | G | 90 | Liver | 0.6 (0.4) | Hepatocellular adenoma or carcinoma | 5.5 (3.9) | mg/kg | 26194646
Di(2-ethylhexyl) phthalate (117-81-7) | B6C3F1 mouse | M | F | 7 | Liver | 55 (38) | Hepatocellular adenoma or carcinoma | 35 (NA) | adjusted to mg/kg | 27562560
Coal tar extract (NA) | Muta™ Mouse | M | G | 28 | Lung | 1.6 (1.0) | Lung tumor | 2.5 (1.5) | mg/kg | 27858113
Acrylamide (79-06-1) | F344/ DuCrl rat | M | DW | 15 | Thyroid | 2.9 (0.68) | Thyroid tumors | 1.4 (0.82) | mg/kg | 28606764
Acrylamide (79-06-1) | F344/ DuCrl rat | M | DW | 31 | Thyroid | 0.81 (0) | Thyroid tumors | 1.4 (0.82) | mg/kg | 28606764
Tetrachloroethylene (127-18-4) | B6C3F1 mouse | M | G | 1 | Kidney | NA (7.5) | Kidney adenoma and adenocarcinoma | NA (63) | HED mg/kg | 28973375
Tetrachloroethylene (127-18-4) | B6C3F1 mouse | M | G | 1 | Liver | NA (139) | Liver adenoma and carcinoma | NA (48) | HED mg/kg | 28973375
Trichloroethylene (79-01-6) | B6C3F1 mouse | M | G | 1 | Kidney | NA (0.029) | Increased kidney/body weight ratio | NA (0.69) | HED mg/kg | 28973375
Trichloroethylene (79-01-6) | B6C3F1 mouse | M | G | 1 | Liver | NA (3.1) | Liver adenoma and carcinoma | NA (3.5) | HED mg/kg | 28973375
Acrylamide (79-06-1) | F344/ DuCrl rat | M | DW | 31 | Testes | 4.8 (3.3) | Peripheral neuropathy | NA (0.43) | mg/kg | 28403741
Acrylamide (79-06-1) | CD-1 mouse | M | DW | 15 | Lung | 2.9 (2.2) | Lung adenoma | 2.1 (1.3) | mg/kg | 29475067
Acrylamide (79-06-1) | CD-1 mouse | M | DW | 31 | Harderian gland | 0.87 (0.54) | Harderian gland adenoma | 0.37 (0.17) | mg/kg | 29475067
Myclobutanil (88671-89-0) | Crl:CD (SD) rat | M | G | 14 | Testes | 50 (25) | Testis seminiferous tubule atrophy (unilateral or bilateral) | 2.9 (1.4) | mg/kg | 32268158
Acrylamide (79-06-1) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.68 (NA) | Peripheral nerve (sciatic) axon degeneration-non neoplastic | 0.61 (0.43) | mg/kg | 32492150
Bromodichloroacetic acid (71133-14-7) | Sprague-Dawley rat | M | G | 5 | Kidney | 1.3 (NA) | Bone marrow angiectasis-non neoplastic | 2.3 (1.9) | mg/kg | 32492150
Coumarin (91-64-5) | Sprague-Dawley rat | M | G | 5 | Liver | 3.0 (NA) | Liver necrosis-non neoplastic | 5.9 (4.9) | mg/kg | 32492150
Pentabromodiphenyl ether mixture (32534-81-9) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.72 (NA) | Hepatocyte hypertrophy-non neoplastic | 0.15 (0.11) | mg/kg | 32492150
Di(2-ethylhexyl) phthalate (117-81-7) | Sprague-Dawley rat | M | G | 5 | Liver | 23 (NA) | Testis degeneration seminiferous tubules-non neoplastic | 184 (155) | mg/kg | 32492150
Ethinyl estradiol (57-63-6) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.19 (NA) | Mammary gland alveolar hyperplasia-non neoplastic | 0.69 (0.47) | µg/kg | 32492150
Furan (110-00-9) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.61 (NA) | Liver cholangiofibrosis-non neoplastic | 0.10 (0.09) | mg/kg | 32492150
Hexachlorobenzene (118-74-1) | Sprague-Dawley rat | M | G | 5 | Liver | 4.6 (NA) | Kidney chronic nephrosis (severe)-non neoplastic | 0.59 (0.35) | mg/kg | 32492150
Methyl eugenol (93-15-2) | Sprague-Dawley rat | M | G | 5 | Liver | 33 (NA) | Hepatocellular adenoma or carcinoma | 12 (9.9) | mg/kg | 32492150
Perfluorooctanoic acid (335-67-1) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.11 (NA) | Hepatocyte hypertrophy-non neoplastic | 0.50 (0.41) | mg/kg | 32492150
Pulegone (89-82-7) | Sprague-Dawley rat | M | G | 5 | Liver | 21 (NA) | Nasal olfactory epithelium degeneration-non neoplastic | 14.2 (9.5) | mg/kg | 32492150
3,3’,4,4’-Tetrachloroazobenzene (14047-09-7) | Sprague-Dawley rat | M | G | 5 | Kidney | 1.7 (NA) | Forestomach epithelium hyperplasia-non neoplastic | 2.9 (2.13) | mg/kg | 32492150
α,β-Thujone (76231-76-0) | Sprague-Dawley rat | M | G | 5 | Kidney | 141 (NA) | Kidney mineralization-non neoplastic | 3.2 (2.3) | mg/kg | 32492150
Fenpicoxamid (517875-34-2) | Sprague-Dawley rat | M | F | 90 | Kidney | 115 (59) | Kidney, chronic progressive glomerulonephropathy, slight | NA (140) | adjusted to mg/kg | 33217531
Pronamide (23950-58-5) | F344/ DuCrl rat | M | F | 90 | Liver | 5.6 (2.5) | Liver weight, relative | NA (8.5) | adjusted to mg/kg | 33217531
Sulfoxaflor (946578-00-3) | F344/ DuCrl rat | M | F | 90 | Liver | 6.1 (4.0) | Testis adenoma, unilateral, bilateral and unilateral combined | NA (1.0) | adjusted to mg/kg | 33217531
Triclopyr Acid (55335-06-3) | F344/ DuCrl rat | M | F | 90 | Kidney | 5.4 (3.0) | Relative kidney weight | NA (4.0) | adjusted to mg/kg | 33217531
Dichloroacetic acid (79-43-6) | B6C3F1 mouse | M | DW | 6 | Liver | 134 (101) | Hepatocellular adenoma or carcinoma | 44 (13) | adjusted to mg/kg | 36518475

Legend: Sex: (M) Male and (F) Female | Exposure Route: (DW) Drinking Water, (F) Feed, (G) Gavage, (I) Inhalation | BMD: Benchmark dose, BMD(L): Benchmark dose lower confidence limit, CASRN: Chemical Abstracts Service Registry Number, d: Day, HED: Human equivalent dose, NA: Not available

Table 6-11 Rat and mouse transcriptomic BMD(L) values for lowest gene set in liver and kidney tissue from 1 to 90-day exposures and BMD(L) values for traditional non-cancer and cancer endpoints from rodent bioassays reported in literature search. The data used to create Figure 3-2

Chemical (CASRN) | Species and strain/ stock | Sex | Route | Gene Expression Timepoint (d) | Gene Expression Tissue | Lowest Transcriptomic BMD (BMDL) | Endpoint | Lowest Traditional Endpoint BMD (BMDL) | BMD(L) Units | Study PubMed ID
Acrylamide (79-06-1) | Sprague-Dawley rat | M | G | 5 | Liver | 4.7 (NA) | Peripheral nerve (sciatic) axon degeneration-non neoplastic | 0.61 (0.43) | mg/kg | 32492150
Acrylamide (79-06-1) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.68 (NA) | Peripheral nerve (sciatic) axon degeneration-non neoplastic | 0.61 (0.43) | mg/kg | 32492150
Bromodichloroacetic acid (71133-14-7) | Sprague-Dawley rat | M | G | 5 | Liver | 2.8 (NA) | Bone marrow angiectasis-non neoplastic | 2.3 (1.9) | mg/kg | 32492150
Bromodichloroacetic acid (71133-14-7) | Sprague-Dawley rat | M | G | 5 | Kidney | 1.3 (NA) | Bone marrow angiectasis-non neoplastic | 2.3 (1.9) | mg/kg | 32492150
Coumarin (91-64-5) | Sprague-Dawley rat | M | G | 5 | Kidney | 21 (NA) | Liver necrosis-non neoplastic | 5.9 (4.9) | mg/kg | 32492150
Pentabromodiphenyl ether mixture (32534-81-9) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.72 (NA) | Hepatocyte hypertrophy-non neoplastic | 0.15 (0.11) | mg/kg | 32492150
Di(2-ethylhexyl) phthalate (117-81-7) | Sprague-Dawley rat | M | G | 5 | Liver | 23 (NA) | Testis degeneration seminiferous tubules-non neoplastic | 184 (155) | mg/kg | 32492150
Di(2-ethylhexyl) phthalate (117-81-7) | Sprague-Dawley rat | M | G | 5 | Kidney | 44 (NA) | Testis degeneration seminiferous tubules-non neoplastic | 184 (155) | mg/kg | 32492150
Ethinyl estradiol (57-63-6) | Sprague-Dawley rat | M | G | 5 | Liver | 1.8 (NA) | Mammary gland alveolar hyperplasia-non neoplastic | 0.69 (0.47) | µg/kg | 32492150
Ethinyl estradiol (57-63-6) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.19 (NA) | Mammary gland alveolar hyperplasia-non neoplastic | 0.69 (0.47) | µg/kg | 32492150
Furan (110-00-9) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.61 (NA) | Liver cholangiofibrosis-non neoplastic | 0.10 (0.09) | mg/kg | 32492150
Hexachlorobenzene (118-74-1) | Sprague-Dawley rat | M | G | 5 | Liver | 4.6 (NA) | Kidney chronic nephrosis (severe)-non neoplastic | 0.59 (0.35) | mg/kg | 32492150
Methyl eugenol (93-15-2) | Sprague-Dawley rat | M | G | 5 | Kidney | 116 (NA) | Hepatocellular adenoma or carcinoma | 12 (9.9) | mg/kg | 32492150
Perfluorooctanoic acid (335-67-1) | Sprague-Dawley rat | M | G | 5 | Kidney | 0.11 (NA) | Hepatocyte hypertrophy-non neoplastic | 0.50 (0.41) | mg/kg | 32492150
Pulegone (89-82-7) | Sprague-Dawley rat | M | G | 5 | Liver | 21 (NA) | Nasal olfactory epithelium degeneration-non neoplastic | 14 (9.5) | mg/kg | 32492150
Pulegone (89-82-7) | Sprague-Dawley rat | M | G | 5 | Kidney | 22(NA) | Nasal olfactory epithelium degeneration-non neoplastic | 14 (9.5) | mg/kg | 32492150
3,3’,4,4’-Tetrachloroazobenzene (14047-09-7) | Sprague-Dawley rat | M | G | 5 | Liver | 12 (NA) | Forestomach epithelium hyperplasia-non neoplastic | 2.9 (2.1) | mg/kg | 32492150
3,3’,4,4’-Tetrachloroazobenzene (14047-09-7) | Sprague-Dawley rat | M | G | 5 | Kidney | 1.7 (NA) | Forestomach epithelium hyperplasia-non neoplastic | 2.9 (2.1) | mg/kg | 32492150
α,β-Thujone (76231-76-0) | Sprague-Dawley rat | M | G | 5 | Liver | 151 (NA) | Kidney mineralization-non neoplastic | 3.2 (2.3) | mg/kg | 32492150
Tetrachloroethylene (127-18-4) | B6C3F1 mouse | M | G | 1 | Liver | NA (139) | Kidney adenoma and adenocarcinoma | NA (63) | HED mg/kg | 28973375
Tetrachloroethylene (127-18-4) | B6C3F1 mouse | M | G | 1 | Kidney | NA (7.5) | Liver adenoma and carcinoma | NA (48) | HED mg/kg | 28973375
Trichloroethylene (79-01-6) | B6C3F1 mouse | M | G | 1 | Liver | NA (3.1) | Increased kidney/body weight ratio | NA (0.69) | HED mg/kg | 28973375
Trichloroethylene (79-01-6) | B6C3F1 mouse | M | G | 1 | Kidney | NA (0.029) | Liver adenoma and carcinoma | NA (3.5) | HED mg/kg | 28973375
Methylene chloride (75-09-2) | B6C3F1 mouse | F | I | 91 | Liver | 1265 (728) | Lung adenoma and carcinoma | 791 (632) | mg/m^3^ | 21097997
Acrylamide (79-06-1) | F344/DuCrl rat | M | DW | 31 | Liver | 3.8 (1.9) | Thyroid tumors | 1.4 (0.82) | mg/kg | 28606764
Sulfoxaflor (946578-00-3) | F344/DuCrl rat | M | F | 90 | Liver | 6.1 (4.0) | Testis adenoma, unilateral, bilateral and unilateral combined | NA (1.0) | adjusted to mg/kg | 33217531
Triclopyr Acid (55335-06-3) | F344/DuCrl rat | M | F | 90 | Liver | 31 (9.3) | Relative kidney weight | NA (4.0) | adjusted to mg/kg | 33217531

Legend: Sex: (M) Male and (F) Female | Exposure Route: (DW) Drinking Water, (F) Feed, (G) Gavage, (I) Inhalation | BMD: Benchmark dose, BMD(L): Benchmark dose lower confidence limit, CASRN: Chemical Abstracts Service Registry Number, d: Day, HED: Human equivalent dose, NA: Not available

Table 6-12 Rat and mouse transcriptomic BMD(L) values for the lowest gene set from 1 to 90-day exposures collected using microarray, TempO-Seq, and RNA-seq platforms and BMD(L) values for traditional non-cancer and cancer endpoints from rodent bioassays reported in literature search. The data used to create Figure 3-3

Chemical (CASRN) | Species and strain/ stock | Sex | Platform | Route | Gene Expression Timepoint (d) | Gene Expression Tissue | Lowest Transcriptomic BMD (BMDL) | Endpoint | Lowest Traditional Endpoint BMD (BMDL) | BMD(L) Units | Study PubMed ID
Paraformaldehyde (30525-89-4) | F344/ NCrl rat | M | Array | I | 1 | Nasal epithelium | 1.6 (1.1) | Nasal epithelium cell proliferation | 4.9 (3.8) | ppm | 17449896
Paraformaldehyde (30525-89-4) | F344/ CrlBR rat | M | Array | I | 7 | Nasal epithelium | 3.7 (2.7) | Nasal epithelium cell proliferation | 4.9 (3.8) | ppm | 20884683
Paraformaldehyde (30525-89-4) | F344/ CrlBR rat | M | Array | I | 28 | Nasal epithelium | 4.0 (2.7) | Nasal epithelium cell proliferation | 4.9 (3.8) | ppm | 20884683
Paraformaldehyde (30525-89-4) | F344/ CrlBR rat | M | Array | I | 91 | Nasal epithelium | 2.7 (1.9) | Nasal epithelium cell proliferation | 4.9 (3.8) | ppm | 20884683
Fenofibrate (49562-28-9) | Rat | F | Array | G | 2 | Liver | 4.7 (3.3) | Hepatocellular carcinoma | 57 (40) | mg/kg | 20801182
Methapyrilene (135-23-9) | Sprague-Dawley rat | M | Array | G | 7 | Liver | 29 (11) | Hepatocellular carcinoma | 7.0 (4.0) | mg/kg | 20801182
1,4-Dichlorobenzene (106-46-7) | B6C3F1 mouse | F | Array | G | 91 | Liver | 65 (38) | Liver adenoma and carcinoma | 218 (158) | mg/kg | 21097997
Methylene chloride (75-09-2) | B6C3F1 mouse | F | Array | I | 91 | Lung | 1137 (694) | Lung adenoma and carcinoma | 791 (632) | mg/m3 | 21097997
Methylene chloride (75-09-2) | B6C3F1 mouse | F | Array | I | 91 | Liver | 1265 (728) | Liver adenoma and carcinoma | 3545 (1931) | mg/m3 | 21097997
Naphthalene (91-20-3) | B6C3F1 mouse | F | Array | I | 91 | Lung | 17 (10) | Lung adenoma and carcinoma | 120 (92) | mg/m3 | 21097997
Propylene glycol mono-t-butyl ether (57018-52-7) | B6C3F1 mouse | F | Array | I | 91 | Liver | 677 (388) | Liver adenoma and carcinoma | 1774 (866) | mg/m3 | 21097997
1,2,3-trichloropropane (96-18-4) | B6C3F1 mouse | F | Array | G | 91 | Liver | 7.4 (4.0) | Liver adenoma and carcinoma | 2.8 (1.3) | mg/kg | 21097997
β-Chloroprene (126-99-8) | B6C3F1/ Crl mouse | F | Array | I | 5 | Lung | 1.8 (1.1) | Time-to-lung tumor | 1.2 (0.88) | ppm | 23125180
β-Chloroprene (126-99-8) | B6C3F1/ Crl mouse | F | Array | I | 15 | Lung | 5.9 (3.9) | Time-to-lung tumor | 1.2 (0.88) | ppm | 23125180
β-Chloroprene (126-99-8) | F344/ NCrl rat | F | Array | I | 5 | Lung | 38 (24) | Lung tumor | 102 (76) | ppm | 23125180
β-Chloroprene (126-99-8) | F344/ NCrl rat | F | Array | I | 15 | Lung | 12 (8.0) | Lung tumor | 102 (76) | ppm | 23125180
4,4′-Methylenebis (N,N-dimethyl) benzenamine (101-61-1) | F344 rat | F | Array | F | 5 | Thyroid | 17 (13) | Thyroid follicular cell carcinoma and adenoma | 30.1 (22.4) | adjusted to mg/kg | 23596260
4,4′-Methylenebis (N,N-dimethyl) benzenamine (101-61-1) | F344 rat | F | Array | F | 14 | Thyroid | 23 (14) | Thyroid follicular cell carcinoma and adenoma | 30 (22) | adjusted to mg/kg | 23596260
4,4′-Methylenebis (N,N-dimethyl) benzenamine (101-61-1) | F344 rat | F | Array | F | 28 | Thyroid | 20 (11.9) | Thyroid follicular cell carcinoma and adenoma | 30 (22) | adjusted to mg/kg | 23596260
4,4′-Methylenebis (N,N-dimethyl) benzenamine (101-61-1) | F344 rat | F | Array | F | 91 | Thyroid | 21 (12) | Thyroid follicular cell carcinoma and adenoma | 30 (22) | adjusted to mg/kg | 23596260
Hydrazobenzene (122-66-7) | F344 rat | M | Array | F | 5 | Liver | 7.0 (4.2) | Hepatocellular carcinomas and neoplastic liver nodules | 3 (1.7) | adjusted to mg/kg | 23596260
Hydrazobenzene (122-66-7) | F344 rat | M | Array | F | 14 | Liver | 7.8 (6.1) | Hepatocellular carcinomas and neoplastic liver nodules | 3.0 (1.7) | adjusted to mg/kg | 23596260
Hydrazobenzene (122-66-7) | F344 rat | M | Array | F | 28 | Liver | 6.3 (4.0) | Hepatocellular carcinomas and neoplastic liver nodules | 3.0 (1.7) | adjusted to mg/kg | 23596260
Hydrazobenzene (122-66-7) | F344 rat | M | Array | F | 91 | Liver | 3.6 (2.0) | Hepatocellular carcinomas and neoplastic liver nodules | 3.0 (1.7) | adjusted to mg/kg | 23596260
N-Nitrosodiphenylamine (86-30-6) | F344 rat | F | Array | F | 5 | Bladder | 173 (130) | Transitional cell carcinoma of the bladder | 184 (138) | adjusted to mg/kg | 23596260
N-Nitrosodiphenylamine (86-30-6) | F344 rat | F | Array | F | 14 | Bladder | 104 (66) | Transitional cell carcinoma of the bladder | 184 (138) | adjusted to mg/kg | 23596260
N-Nitrosodiphenylamine (86-30-6) | F344 rat | F | Array | F | 28 | Bladder | 162 (124) | Transitional cell carcinoma of the bladder | 184 (138) | adjusted to mg/kg | 23596260
N-Nitrosodiphenylamine (86-30-6) | F344 rat | F | Array | F | 91 | Bladder | 158 (122) | Transitional cell carcinoma of the bladder | 184 (138) | adjusted to mg/kg | 23596260
Cyproconazole (94361-06-5) | CD-1 mouse | M | Array | F | 30 | Liver | NA (9.0) | Liver adenoma or carcinoma | NA (2.1) | adjusted to mg/kg | 23970803
Epoxiconazole (133855-98-8) | CD-1 mouse | M | Array | F | 30 | Liver | NA (16) | Liver adenoma or carcinoma | NA (33) | adjusted to mg/kg | 23970803
Propiconazole (60207-90-1) | CD-1 mouse | M | Array | F | 30 | Liver | NA (56) | Liver adenoma or carcinoma | NA (65) | adjusted to mg/kg | 23970803
Triadimefon (43121-43-3) | CD-1 mouse | M | Array | F | 30 | Liver | NA (58) | Liver adenoma or carcinoma | NA (270) | adjusted to mg/kg | 23970803
Furan (110-00-9)^*^ | B3C6F1 mouse | F | Array | G | 21 | Liver | 1.9 (1.4) | Hepatocellular adenoma | 2.3 (1.3) | mg/kg | 24183702
Benzo(a)pyrene (50-32-8) | B6C3F1 mouse | M | Array | G | 3 | Liver | 0.30 (0.20) | Liver tumor | 1.8 (1.2) | mg/kg | 25605026
Benzo(a)pyrene (50-32-8) | Muta™M ouse | M | Array | G | 28 | Liver | 25 (5.3) | Liver tumor | 1.8 (1.2) | mg/kg | 25605026
Furan (110-00-9)^*^ | B6C3F1 mouse | F | RNA-Seq | G | 21 | Liver | 1.7 (1.0) | Hepatocellular adenoma or carcinoma | 2.3 (1.3) | mg/kg | 26313361
Furan (110-00-9) | F344 rat | M | Array | G | 90 | Liver | 0.08 (0.05) | Hepatocellular adenoma or carcinoma | 1.8 (1.3) | mg/kg | 26194646
Furan (110-00-9) | F344 rat | F | Array | G | 90 | Liver | 0.60 (0.40) | Hepatocellular adenoma or carcinoma | 5.5 (3.9) | mg/kg | 26194646
Di(2-ethylhexyl) phthalate (117-81-7) | B6C3F1 mouse | M | RNA-Seq | F | 7 | Liver | 55 (38) | Hepatocellular adenoma or carcinoma | 35 (NA) | adjusted to mg/kg | 27562560
Coal tar extract (NA) | Muta™M ouse | M | Array | G | 28 | Lung | 1.6 (1.0) | Lung tumor | 2.5 (1.5) | mg/kg | 27858113
Acrylamide (79-06-1) | F344/Du Crl rat | M | RNA-Seq | DW | 15 | Thyroid | 2.9 (0.7) | Thyroid tumors | 1.4 (0.82) | mg/kg | 28606764
Acrylamide (79-06-1) | F344/Du Crl rat | M | RNA-Seq | DW | 31 | Thyroid | 0.81 (0) | Thyroid tumors | 1.4 (0.82) | mg/kg | 28606764
Tetrachloroethylene (127-18-4) | B6C3F1 mouse | M | RNA-Seq | G | 1 | Kidney | NA (7.5) | Kidney adenoma and adenocarcinoma | NA (63) | HED mg/kg | 28973375
Tetrachloroethylene (127-18-4) | B6C3F1 mouse | M | RNA-Seq | G | 1 | Liver | NA (139) | Liver adenoma and carcinoma | NA (48) | HED mg/kg | 28973375
Trichloroethylene (79-01-6) | B6C3F1 mouse | M | RNA-Seq | G | 1 | Kidney | NA (0.029) | Increased kidney/body weight ratio | NA (0.69) | HED mg/kg | 28973375
Trichloroethylene (79-01-6) | B6C3F1 mouse | M | RNA-Seq | G | 1 | Liver | NA (3.1) | Liver adenoma and carcinoma | NA (3.5) | HED mg/kg | 28973375
Acrylamide (79-06-1) | F344/Du Crl rat | M | RNA-Seq | DW | 31 | Testes | 4.8 (3.3) | Preputial gland: duct ectasia | 0.11 (0.015) | mg/kg | 28403741
Acrylamide (79-06-1) | CD-1 mouse | M | RNA-Seq | DW | 15 | Lung | 2.9 (2.2) | Lung adenoma | 2.1 (1.3) | mg/kg | 29475067
Acrylamide (79-06-1) | CD-1 mouse | M | RNA-Seq | DW | 31 | Harderian gland | 0.87 (0.54) | Harderian gland adenoma | 0.37 (0.17) | mg/kg | 29475067
Myclobutanil (88671-89-0) | Crl:CD (SD) rat | M | RNA-Seq | G | 14 | Testes | 50 (25) | Testis seminiferous tubule atrophy (unilateral or bilateral) | 2.9 (1.4) | mg/kg | 32268158
Acrylamide (79-06-1) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 4.7 (NA) | Peripheral nerve (sciatic) axon degeneration-non neoplastic | 0.61 (0.43) | mg/kg | 32492150
Acrylamide (79-06-1) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 0.68 (NA) | Peripheral nerve (sciatic) axon degeneration-non neoplastic | 0.61 (0.43) | mg/kg | 32492150
Bromodichloroacetic acid (71133-14-7) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 2.8 (NA) | Bone marrow angiectasis-non neoplastic | 2.3 (1.9) | mg/kg | 32492150
Bromodichloroacetic acid (71133-14-7) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 1.3 (NA) | Bone marrow angiectasis-non neoplastic | 2.3 (1.9) | mg/kg | 32492150
Coumarin (91-64-5) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 3.0 (NA) | Liver necrosis-non neoplastic | 5.9 (4.9) | mg/kg | 32492150
Coumarin (91-64-5) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 21 (NA) | Liver necrosis-non neoplastic | 5.9 (4.9) | mg/kg | 32492150
Pentabromodiphenyl ether mixture (32534-81-9) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 10 (NA) | Hepatocyte hypertrophy-non neoplastic | 0.15 (0.11) | mg/kg | 32492150
Pentabromodiphenyl ether mixture (32534-81-9) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 0.72 (NA) | Hepatocyte hypertrophy-non neoplastic | 0.15 (0.11) | mg/kg | 32492150
Di(2-ethylhexyl) phthalate (117-81-7) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 23 (NA) | Testis degeneration seminiferous tubules-non neoplastic | 184 (155) | mg/kg | 32492150
Di(2-ethylhexyl) phthalate (117-81-7) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 44 (NA) | Testis degeneration seminiferous tubules-non neoplastic | 184 (155) | mg/kg | 32492150
Ethinyl estradiol (57-63-6) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 1.8 (NA) | Mammary gland alveolar hyperplasia-non neoplastic | 0.69 (0.47) | ug/kg | 32492150
Ethinyl estradiol (57-63-6) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 0.19 (NA) | Mammary gland alveolar hyperplasia-non neoplastic | 0.69 (0.47) | µg/kg | 32492150
Furan (110-00-9) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 1.2 (NA) | Liver cholangiofibrosis-non neoplastic | 0.1 (0.09) | mg/kg | 32492150
Furan (110-00-9) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 0.61 (NA) | Liver cholangiofibrosis-non neoplastic | 0.10 (0.09) | mg/kg | 32492150
Hexachlorobenzene (118-74-1) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 4.6 (NA) | Kidney chronic nephrosis (severe)-non neoplastic | 0.59 (0.35) | mg/kg | 32492150
Hexachlorobenzene (118-74-1) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 4.6 (NA) | Adrenal gland adrenal pheochromocytoma | 1.2 (0.60) | mg/kg | 32492150
Methyl eugenol (93-15-2) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 33 (NA) | Hepatocellular adenoma or carcinoma | 12 (9.9) | mg/kg | 32492150
Methyl eugenol (93-15-2) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 116 (NA) | Hepatocellular adenoma or carcinoma | 12 (9.9) | mg/kg | 32492150
Perfluorooctanoic acid (335-67-1) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 0.35 (NA) | Hepatocyte hypertrophy-non neoplastic | 0.50 (0.41) | mg/kg | 32492150
Perfluorooctanoic acid (335-67-1) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 0.11 (NA) | Hepatocyte hypertrophy-non neoplastic | 0.50 (0.41) | mg/kg | 32492150
Pulegone (89-82-7) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 21 (NA) | Nasal olfactory epithelium degeneration-non neoplastic | 14 (9.5) | mg/kg | 32492150
Pulegone (89-82-7) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 22 (NA) | Nasal olfactory epithelium degeneration-non neoplastic | 14 (9.5) | mg/kg | 32492150
3,3’,4,4’-Tetrachloroazobenzene (14047-09-7) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 12 (NA) | Forestomach epithelium hyperplasia-non neoplastic | 2.9 (2.1) | mg/kg | 32492150
3,3’,4,4’-Tetrachloroazobenzene (14047-09-7) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 1.7 (NA) | Forestomach epithelium hyperplasia-non neoplastic | 2.9 (2.1) | mg/kg | 32492150
α,β-Thujone (76231-76-0) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Liver | 151 (NA) | Kidney mineralization-non neoplastic | 3.2 (2.3) | mg/kg | 32492150
α,β-Thujone (76231-76-0) | Sprague-Dawley rat | M | TempO-Seq | G | 5 | Kidney | 141 (NA) | Kidney mineralization-non neoplastic | 3.2 (2.3) | mg/kg | 32492150
Fenpicoxamid (517875-34-2) | Sprague-Dawley rat | M | RNA-Seq | F | 90 | Kidney | 115 (59) | Kidney, chronic progressive glomerulonephropathy, slight | NA (140) | adjusted to mg/kg | 33217531
Pronamide (23950-58-5) | F344/Du Crl rat | M | RNA-Seq | F | 90 | Liver | 5.6 (2.5) | Liver weight, relative | NA (8.5) | adjusted to mg/kg | 33217531
Sulfoxaflor (946578-00-3) | F344/Du Crl rat | M | RNA-Seq | F | 90 | Liver | 6.1 (4.0) | Testis adenoma, unilateral, bilateral and unilateral combined | NA (1.0) | adjusted to mg/kg | 33217531
Triclopyr Acid (55335-06-3) | F344/Du Crl rat | M | RNA-Seq | F | 90 | Liver | 31 (9.3) | Relative kidney weight | NA (4.0) | adjusted to mg/kg | 33217531
Triclopyr Acid (55335-06-3) | F344/Du Crl rat | M | RNA-Seq | F | 90 | Kidney | 5.4 (3.0) | Relative kidney weight | NA (4.0) | adjusted to mg/kg | 33217531
Dichloroacetic acid (79-43-6)^*^ | B6C3F1 mouse | M | RNA-Seq | DW | 6 | Liver | 94 (74) | Hepatocellular adenoma or carcinoma | 44 (13) | adjusted to mg/kg | 36518475
Dichloroacetic acid (79-43-6)^*^ | B6C3F1 mouse | M | TempO-Seq | DW | 6 | Liver | 134 (101) | Hepatocellular adenoma or carcinoma | 44 (13) | adjusted to mg/kg | 36518475

Legend: Sex: (M) Male and (F) Female | Exposure Route: (DW) Drinking Water, (F) Feed, (G) Gavage, (I) Inhalation | Platform: (Array) Microarray | BMD: Benchmark dose, BMD(L): Benchmark dose lower confidence limit, CASRN: Chemical Abstracts Service Registry Number, d: Day, HED: Human equivalent dose, NA: Not available;

* Paired data; the same samples have conventional RNA-Seq and TempO-Seq data.