# ABBREVIATIONS

ANOVA: Analysis of Variance
AIC: Akaike Information Criterion
ATSDR: Agency for Toxic Substances and Disease Registry
BCTD: Biomolecular and Computational Toxicology Division
BMD: Benchmark Dose
BMD(L): Refers to the BMD and/or BMDL
BMDL: Benchmark Dose Lower Confidence Bound
BMDS: Benchmark Dose Modeling Software
BMDU: Benchmark Dose Upper Confidence Bound
BMR: Benchmark Response
BOSC: EPA Board of Scientific Counselors
CASRN: Chemical Abstracts Service Registry Number
CCCB: Computational Chemistry and Cheminformatics Branch
CCED: Chemical Characterization and Exposure Division
CCTE: Center for Computational Toxicology and Exposure
CDx: Companion Diagnostics
CPAD: Chemical and Pollutant Assessment Division
CPHEA: Center for Public Health and Environmental Assessment
CPM: Counts per Million
CTBB: Computational Toxicology and Bioinformatics Branch
DNTP: Division of the National Toxicology Program of the National Institute of Environmental Health Sciences
DTT: Division of Translational Toxicology of the National Institute of Environmental Health Sciences, formerly known as the Division of the National Toxicology Program (DNTP)
DWS: Drinking Water Standards
EPA: U.S. Environmental Protection Agency
ECHA: European Chemicals Agency
ENBS: Expected Net Benefit of Sampling
ETAP: EPA Transcriptomic Assessment Product
ETTB: Experimental Toxicokinetics and Toxicodynamics Branch
FC: Fold Change
FDA: U.S. Food and Drug Administration
FDR: False Discovery Rate
FIFRA: Federal Insecticide, Fungicide, and Rodenticide Act
GO: Gene Ontology
ID: Identifier
IRIS: EPA Integrated Risk Information System
KOW: n-Octanol/Water Partition Coefficient
LOAEL: Lowest Observable Adverse Effect Level
MAQC: The MicroArray Quality Consortium
MRL: Minimum Risk Level
mRNA: Messenger Ribonucleic Acid (RNA)
MSD: Mean Squared Difference
MAD: Median Absolute Deviation
NAM: New Approach Methodology
NASEM: U.S. National Academies for Science, Engineering, and Medicine
NGS: Next-Generation Sequencing
NIEHS: National Institute of Environmental Health Sciences
NIH: National Institutes of Health
NOAEL: No Observable Adverse Effect Level
NTP: National Toxicology Program
OECD: Organization for Economic Cooperation and Development
OPP: EPA Office of Pesticide Program
ORD: Office of Research and Development
OW: EPA Office of Water
PBPK: Physiologically Based Pharmacokinetic
PC/PCA: Principal Component / Principal Component Analysis
PFAS: Per- and Polyfluoralkyl Substances
POD: Point-of-Departure
PPARα: Peroxisome Proliferator Activated Receptor α
PPRTV: Provisional Peer Reviewed Toxicity Value
REACH: Registration, Evaluation, Authorisation and Restriction of Chemicals
RfD: Reference Dose
RMSD: Root- Mean-Square Difference
RMSE: Root- Mean-Square Error
RNA-Seq: Ribonucleic Acid (RNA) Sequencing
RT-PCR: Reverse Transcription Polymerase Chain Reaction
SD: Standard Deviation
SEQC: Sequencing Quality Control
TEAB: Toxic Effects Assessment Branch
TG-GATES: Toxicogenomics Project-Genomics Assisted Toxicity Evaluation System
THHA: Traditional Human Health Assessment
TSCA: Toxic Substances Control Act
TRV: Transcriptomic Reference Value
UF: Uncertainty Factor
VOI: Value of Information