# REFERENCES

Ahrens, L. (2011). Polyfluoroalkyl compounds in the aquatic environment: a review of their occurrence and fate [Review]. J Environ Monit 13: 20–31. 10.1039/c0em00373e.21031178
Antoniou, E; Colnot, T; Zeegers, M; Dekant, W. (2022). Immunomodulation and exposure to per- and polyfluoroalkyl substances: an overview of the current evidence from animal and human studies [Review]. Arch Toxicol 96: 2261–2285. 10.1007/s00204-022-03303-4.35695909
ATSDR (Agency for Toxic Substances and Disease Registry). (2021). Toxicological profile for perfluoroalkyls [ATSDR Tox Profile]. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service. 10.15620/cdc:59198.
Bangma, J; Szilagyi, J; Blake, BE; Plazas, C; Kepper, S; Fenton, SE; C Fry, R. (2020). An assessment of serum-dependent impacts on intracellular accumulation and genomic response of per- and polyfluoroalkyl substances in a placental trophoblast model. Environ Toxicol 35: 1395–1405. 10.1002/tox.23004.32790152
Bannach-Brown, A; Przybyła, P; Thomas, J; Rice, ASC; Ananiadou, S; Liao, J; Macleod, MR. (2018). Machine learning algorithms for systematic review: reducing workload in a preclinical review of animal studies and reducing human screening error (pp. 1-26). bioRxiv. 10.1101/255760.
Beach, SA; Newsted, JL; Coady, K; Giesy, JP. (2006). Ecotoxicological evaluation of perfluorooctanesulfonate (PFOS) [Review]. Rev Environ Contam Toxicol 186: 133–174. 10.1007/0-387-32883-1_5.16676904
Behnisch, PA; Besselink, H; Weber, R; Willand, W; Huang, J, un; Brouwer, A. (2021). Developing potency factors for thyroid hormone disruption by PFASs using TTR-TR beta CALUX (R) bioassay and assessment of PFASs mixtures in technical products. Environ Int 157: 106791. 10.1016/j.envint.2021.106791.34364217
Blake, BE; Miller, CN; Nguyen, H; Chappell, VA; Phan, TP; Phadke, DP; Balik-Meisner, MR; Mav, D; Shah, RR; Fenton, SE. (2022). Transcriptional pathways linked to fetal and maternal hepatic dysfunction caused by gestational exposure to perfluorooctanoic acid (PFOA) or hexafluoropropylene oxide-dimer acid (HFPO-DA or GenX) in CD-1 mice. Ecotoxicol Environ Saf 248: 114314–114314. 10.1016/j.ecoenv.2022.114314.36436258
Bohannon, ME; Narizzano, AM; Guigni, BA; East, AG; Quinn, MJ. (2023). Next-generation PFAS 6:2 fluorotelomer sulfonate reduces plaque formation in exposed white-footed mice. Toxicol Sci 192: 97–105. 10.1093/toxsci/kfad006.36629485
Buck, RC; Franklin, J; Berger, U; Conder, JM; Cousins, IT; de Voogt, P; Jensen, AA; Kannan, K; Mabury, SA; van Leeuwen, SP. (2011). Perfluoroalkyl and polyfluoroalkyl substances in the environment: terminology, classification, and origins [Review]. Integr Environ Assess Manag 7: 513–541. 10.1002/ieam.258.21793199
Calafat, AM; Kato, K; Hubbard, K; Jia, T; Botelho, JC; Wong, LY. (2019). Legacy and alternative per- and polyfluoroalkyl substances in the U.S. general population: Paired serum-urine data from the 2013-2014 National Health and Nutrition Examination Survey. Environ Int 131: 105048. 10.1016/j.envint.2019.105048.31376596
Calafat, AM; Wong, LY; Kuklenyik, Z; Reidy, JA; Needham, LL. (2007). Polyfluoroalkyl chemicals in the US population: Data from the National Health and Nutrition Examination Survey (NHANES) 2003-2004 and comparisons with NHANES 1999-2000. Environ Health Perspect 115: 1596–1602. 10.1289/ehp.10598.18007991
Carlson, LA; Angrish, M; Shirke, AV; Radke, EG; Schulz, B; Kraft, A; Judson, R; Patlewicz, G; Blain, R; Lin, C; Vetter, N; Lemeris, C; Hartman, P; Hubbard, H; Arzuaga, X; Davis, A; Dishaw, LV; Druwe, IL; Hollinger, H; … Thayer, KA. (2022). Systematic evidence map for over one hundred and fifty per- and polyfluoroalkyl substances (PFAS) [Review]. Environ Health Perspect 130: 56001. 10.1289/EHP10343.35580034
Carlson, LA; Angrish, M; Shirke, AV; Radke, EG; Schulz, B; Kraft, A; Judson, R; Patlewicz, G; Blain, R; Lin, C; Vetter, N; Lemeris, C; Hartman, P; Hubbard, H; Arzuaga, X; Davis, A; Dishaw, LV; Druwe, IL; Hollinger, H; … Thayer, KA. (2024). Erratum: Systematic evidence map for over one hundred and fifty per- and polyfluoroalkyl substances (PFAS) [Erratum]. 132. 10.1289/EHP14191.
Cohen, AM; Hersh, WR; Peterson, K; Yen, PY. (2006). Reducing workload in systematic review preparation using automated citation classification. J Am Med Inform Assoc 13: 206–219. 10.1197/jamia.M1929.16357352
DeWitt, JC. (2015). Toxicological effects of perfluoroalkyl and polyfluoroalkyl substances. New York, NY: Springer International. 10.1007/978-3-319-15518-0.
Dewitt, JC; Blossom, SJ; Schaider, LA. (2019). Exposure to per-fluoroalkyl and polyfluoroalkyl substances leads to immunotoxicity: Epidemiological and toxicological evidence [Review]. J Expo Sci Environ Epidemiol 29: 148–156. 10.1038/s41370-018-0097-y.30482935
Dong, GH; Zhang, YH; Zheng, L; Liu, W; Jin, YH; He, QC. (2009). Chronic effects of perfluorooctanesulfonate exposure on immunotoxicity in adult male C57BL/6 mice. Arch Toxicol 83: 805–815. 10.1007/s00204-009-0424-0.19343326
ECHA (European Chemicals Agency). (1995). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Repeated dose toxicity: oral: 003 Supporting | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/24637/7/6/2/?documentUUID=6d6be51f-06c0-4087-b2ff-70cb5a5ddd5c.
ECHA (European Chemicals Agency). (2007a). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Genetic toxicity: in vitro: 002 Key | Experimental result. https://echa.europa.eu/bg/registration-dossier/-/registered-dossier/24637/7/7/2/?documentUUID=bac28259-41fc-4759-a8d4-e0c878d536cb.
ECHA (European Chemicals Agency). (2007b). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Genetic toxicity: in vivo: 002 Key | Experimental result. https://echa.europa.eu/bg/registration-dossier/-/registered-dossier/24637/7/7/3/?documentUUID=48583076-04d9-4fcb-9113-1fbedef24620.
ECHA (European Chemicals Agency). (2007c). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Genetic toxicity: in vivo: 003 Key | Experimental result. https://echa.europa.eu/bg/registration-dossier/-/registered-dossier/24637/7/7/3/?documentUUID=c4818d4b-0699-4463-93ae-ed82d483e5e2.
ECHA (European Chemicals Agency). (2007d). Registration dossier: Potassium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonate (CASRN: 59587-38-1): Genetic toxicity: In vivo: 002 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/24910/7/7/3/?documentUUID=0a7f67ce-4cb1-4e4c-b4f8-0604341df0bd.
ECHA (European Chemicals Agency). (2007e). Registration dossier: Potassium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonate (CASRN: 59587-38-1): Genetic toxicity: In vivo: 003 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/24910/7/7/3/?documentUUID=ce8005bb-12fa-49a5-b966-8d7361b259a4.
ECHA (European Chemicals Agency). (2007f). Registration dossier: Potassium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonate (CASRN: 59587-38-1): Genetic toxicity: In vivo: 004 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/24910/7/7/3/?documentUUID=267add34-7e1a-4ae9-96f7-ce9175501c71.
ECHA (European Chemicals Agency). (2015). Registration dossier: Potassium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonate (CASRN: 59587-38-1): Genetic toxicity: In vivo: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/24910/7/7/3/?documentUUID=69c2ca30-8a60-4919-b7a3-69b22afb06ab.
ECHA (European Chemicals Agency). (2017). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Acute toxicity: oral: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/24637/7/3/2.
ECHA (European Chemicals Agency). (2018a). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Developmental toxicity/teratogenicity: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/24637/7/9/3.
ECHA (European Chemicals Agency). (2018b). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Repeated dose toxicity: oral: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/24637/7/6/2/?documentUUID=b6c90827-a8c7-4ae5-9138-bf852811801d.
ECHA (European Chemicals Agency). (2018c). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Toxicity to reproduction: 001 Key | Experimental result. https://echa.europa.eu/registration-dossier/-/registered-dossier/24637/7/9/2.
ECHA (European Chemicals Agency). (2019a). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Basic toxicokinetics: 001 Supporting | Experimental result. https://echa.europa.eu/bg/registration-dossier/-/registered-dossier/24637/7/2/2.
ECHA (European Chemicals Agency). (2019b). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Basic toxicokinetics: 002 Supporting | Experimental result. https://echa.europa.eu/bg/registration-dossier/-/registered-dossier/24637/7/2/2/?documentUUID=b7b9c663-c5b0-4579-bda5-a02982ff6eb5.
ECHA (European Chemicals Agency). (2019c). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Basic toxicokinetics: 003 Supporting | Experimental result. https://echa.europa.eu/bg/registration-dossier/-/registered-dossier/24637/7/2/2/?documentUUID=cd1c0a57-880d-4078-95e0-37ac0110c8c5.
ECHA (European Chemicals Agency). (2019d). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Genetic toxicity: in vitro: 001 Key | Experimental result. https://echa.europa.eu/bg/registration-dossier/-/registered-dossier/24637/7/7/2.
ECHA (European Chemicals Agency). (2019e). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Genetic toxicity: in vivo: 001 Key | Experimental result. https://echa.europa.eu/bg/registration-dossier/-/registered-dossier/24637/7/7/3.
ECHA (European Chemicals Agency). (2019f). Registration dossier: 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonic acid (CASRN: 27619-97-2): Genetic toxicity: in vivo: 004 Key | Experimental result. https://echa.europa.eu/bg/registration-dossier/-/registered-dossier/24637/7/7/3/?documentUUID=8bdb668a-f83a-48bb-90ea-5646605583a0.
ECHA (European Chemicals Agency). (2020a). Information on Chemicals [Database]. Helsinki, Finland: European Chemicals Agency, European Union. Retrieved from https://echa.europa.eu/information-on-chemicals
ECHA (European Chemicals Agency). (2020b). Registration dossier: Potassium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonate (CASRN: 59587-38-1): Genetic toxicity: In vitro: 003 Key | Read-across (Structural analogue / surrogate). https://echa.europa.eu/registration-dossier/-/registered-dossier/24910/7/7/2/?documentUUID=7f870679-92a9-4573-a528-374512d4ac99.
ECHA (European Chemicals Agency). (2020c). Registration dossier: Potassium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonate (CASRN: 59587-38-1): Genetic toxicity: In vitro: 004 Key | Read-across (Structural analogue / surrogate). https://echa.europa.eu/registration-dossier/-/registered-dossier/24910/7/7/2/?documentUUID=2702eb45-ed9c-4fe7-898c-e794681bd65a.
ECHA (European Chemicals Agency). (2020d). Registration dossier: Potassium 3,3,4,4,5,5,6,6,7,7,8,8,8-tridecafluorooctanesulphonate (CASRN: 59587-38-1): Toxicokinetics, metabolism and distribution: Basic toxicokinetics. https://echa.europa.eu/registration-dossier/-/registered-dossier/24910/7/2/2.
Evidence Partners. (2022). DistillerSR. Retrieved from https://www.evidencepartners.com/products/distillersr-systematic-review-software/
Fenton, SE; Ducatman, A; Boobis, A; DeWitt, JC; Lau, C; Ng, C; Smith, JS; Roberts, SM. (2021). Per- and polyfluoroalkyl substance toxicity and human health review: Current state of knowledge and strategies for informing future research [Review]. Environ Toxicol Chem 40: 606–630. 10.1002/etc.4890.33017053
Fey, ME; Goodrum, PE; Razavi, NR; Whipps, CM; Fernando, S; Anderson, JK. (2022). Is mixtures’ additivity supported by empirical data? A case study of developmental toxicity of PFOS and 6:2 FTS in wildtype zebrafish embryos. Toxics 10: 418. 10.3390/toxics10080418.35893851
Hekster, FM; Laane, RWP, M; de Voogt, P. (2003). Environmental and toxicity effects of perfluoroalkylated substances [Review]. In GW Ware (Ed.), Reviews of environmental contamination and toxicology: Continuation of residue reviews (pp. 99-121). New York, NY: Springer-Verlag. 10.1007/0-387-21731-2_4.
Howard, BE; Phillips, J; Miller, K; Tandon, A; Mav, D; Shah, MR; Holmgren, S; Pelch, KE; Walker, V; Rooney, AA; Macleod, M; Shah, RR; Thayer, K. (2016). SWIFT-Review: A text-mining workbench for systematic review. Syst Rev 5: 87. 10.1186/s13643-016-0263-z.27216467
Howard, BE; Phillips, J; Tandon, A; Maharana, A; Elmore, R; Mav, D; Sedykh, A; Thayer, K; Merrick, BA; Walker, V; Rooney, A; Shah, RR. (2020). SWIFT-Active Screener: Accelerated document screening through active learning and integrated recall estimation. Environ Int 138: 105623. 10.1016/j.envint.2020.105623.32203803
IPCS (International Programme on Chemical Safety). (2012). Guidance for immunotoxicity risk assessment for chemicals. (Harmonization Project Document No. 10). Geneva, Switzerland: World Health Organization. https://apps.who.int/iris/handle/10665/330098.
Liu, QS; Sun, Y; Qu, G; Long, Y; Zhao, X; Zhang, A; Zhou, Q; Hu, L; Jiang, G. (2017). Structure-Dependent Hematological Effects of Per- and Polyfluoroalkyl Substances on Activation of Plasma Kallikrein-Kinin System Cascade. Environ Sci Technol 51: 10173–10183. 10.1021/acs.est.7b02055.28745506
Liu, YZ; Pan, LH; Bai, Y; Yang, K; Dong, PP; Fang, ZZ. (2020). Per- and polyfluoroalkyl substances exert strong inhibition towards human carboxylesterases. Environ Pollut 263: 114463. 10.1016/j.envpol.2020.114463.32283456
Liu, YZ; Zhang, ZP; Fu, ZW; Yang, K; Ding, N; Hu, LG; Fang, ZZ; Zhuo, X. (2019). Per- and polyfluoroalkyl substances display structure-dependent inhibition towards UDP-glucuronosyltransferases. Environ Pollut 254: 113093. 10.1016/j.envpol.2019.113093.31472452
Luster, MI; Munson, AE; Thomas, PT; Holsapple, MP; Fenters, JD; White, KL, Jr; Lauer, LD; Germolec, DR; Rosenthal, GJ; Dean, JH. (1988). Development of a testing battery to assess chemical-induced immunotoxicity: National Toxicology Program’s guidelines for immunotoxicity evaluation in mice [Review]. Toxicol Sci 10: 2–19. 10.1016/0272-0590(88)90247-3.
Luster, MI; Portier, C; Pait, DG; Rosenthal, GJ; Germolec, DR; Corsini, E; Blaylock, BL; Pollock, P; Kouchi, Y; Craig, W. (1993). Risk assessment in immunotoxicology. II. Relationships between immune and host resistance tests. Fundam Appl Toxicol 21: 71–82.8365588
Magnuson, K; Cawley, M; Reilly, D; Varghese, A. (2018). Improving efficiency of systematic reviews through machine learning for automated record deduplication and text analytics for iterative keyword streamlining. Poster presented at Society of Toxicology 57th Annual Meeting and ToxExpo, March 11-15, San Antonio, Texas.
Marques, E; Pfohl, M; Wei, W; Tarantola, G; Ford, L; Amaeze, O; Alesio, J; Ryu, S; Jia, X; Zhu, H; Bothun, GD; Slitt, A. (2022). Replacement per- and polyfluoroalkyl substances (PFAS) are potent modulators of lipogenic and drug metabolizing gene expression signatures in primary human hepatocytes. Toxicol Appl Pharmacol 442: 115991. 10.1016/j.taap.2022.115991.35337807
MI DEGLE (Michigan Department of Environment, Great Lakes, and Energy). (2020). Study results: Targeted and nontargeted analysis of PFAS in fume suppressant products at chrome plating facilities. Lansing, MI: EGLE, Water Resources Division.
Narizzano, AM; Bohannon, ME; East, AG; Mcdonough, C; Choyke, S; Higgins, CP; Quinn, MJ. (2021). Patterns in Serum Toxicokinetics in Peromyscus Exposed to Per- and Polyfluoroalkyl Substances. Environ Toxicol Chem 40: 2886–2898. 10.1002/etc.5151.34236102
NASEM (National Academies of Sciences, Engineering, and Medicine). (2018). Progress toward transforming the Integrated Risk Information System (IRIS) program: A 2018 evaluation. Washington, DC: National Academies Press. 10.17226/25086.
Peden-Adams, MM; Keller, JM; Eudaly, JG; Berger, J; Gilkeson, GS; Keil, DE. (2008). Suppression of humoral immunity in mice following exposure to perfluorooctane sulfonate. Toxicol Sci 104: 144–154. 10.1093/toxsci/kfn059.18359764
Pelch, KE; Reade, A; Wolffe, TAM; Kwiatkowski, CF. (2019). PFAS health effects database: Protocol for a systematic evidence map [Review]. Environ Int 130: 104851. 10.1016/j.envint.2019.05.045.31284092
PFASToxDatabase, T, he Endocrine Disruption Exchange. (2021). PFAS systematic evidence map. PFASToxDatabase, The Endocrine Disruption Exchange. https://pfastoxdatabase.org/.
Radke, E; Wright, MJ; Christensen, K; Lin, CJ; Goldstone, AE; Glenn, B; Thayer, K. (2022). Epidemiology evidence for health effects of 150 per- and polyfluoroalkyl substances: A systematic evidence map [Review]. Environ Health Perspect 130: 96003. 10.1289/EHP11185.36178797
Radke, EG; Braun, JM; Meeker, JD; Cooper, GS. (2018). Phthalate exposure and male reproductive outcomes: A systematic review of the human epidemiological evidence [Review]. Environ Int 121: 764–793. 10.1016/j.envint.2018.07.029.30336412
Rand, AA; Mabury, SA. (2012). In Vitro Interactions of Biological Nucleophiles with Fluorotelomer Unsaturated Acids and Aldehydes: Fate and Consequences. Environ Sci Technol 46: 7398–7406. 10.1021/es3008485.22582947
Sheng, N; Cui, R; Wang, J; Guo, Y; Wang, J; Dai, J. (2018). Cytotoxicity of novel fluorinated alternatives to long-chain perfluoroalkyl substances to human liver cell line and their binding capacity to human liver fatty acid binding protein. Arch Toxicol 92: 359–369. 10.1007/s00204-017-2055-1.28864880
Sheng, N; Zhou, X; Zheng, F; Pan, Y; Guo, X; Guo, Y; Sun, Y; Dai, J. (2017). Comparative hepatotoxicity of 6:2 fluorotelomer carboxylic acid and 6:2 fluorotelomer sulfonic acid, two fluorinated alternatives to long-chain perfluoroalkyl acids, on adult male mice. Arch Toxicol 91: 2909–2919. 10.1007/s00204-016-1917-2.28032147
Shojaei, M; Joyce, AS; Ferguson, PL; Guelfo, JL. (2022). Novel per- and polyfluoroalkyl substances in an active-use C6-based aqueous film forming foam. JHM Letters 3: 100061. 10.1016/j.hazl.2022.100061.
Sunderland, EM; Hu, XC; Dassuncao, C; Tokranov, AK; Wagner, CC; Allen, JG. (2019). A review of the pathways of human exposure to poly- and perfluoroalkyl substances (PFASs) and present understanding of health effects [Review]. J Expo Sci Environ Epidemiol 29: 131–147. 10.1038/s41370-018-0094-1.30470793
U.S. EPA (U.S. Environmental Protection Agency). Health & Environmental Research Online (HERO). https://heronet.epa.gov/heronet/index.cfm/content/home.
U.S. EPA (U.S. Environmental Protection Agency). (1988). Recommendations for and documentation of biological values for use in risk assessment [EPA Report]. (EPA600687008). Cincinnati, OH. http://cfpub.epa.gov/ncea/cfm/recordisplay.cfm?deid=34855.
U.S. EPA (U.S. Environmental Protection Agency). (1994). Methods for derivation of inhalation reference concentrations and application of inhalation dosimetry [EPA Report]. (EPA600890066F). Research Triangle Park, NC. https://cfpub.epa.gov/ncea/risk/recordisplay.cfm?deid=71993&CFID=51174829&CFTOKEN=25006317.
U.S. EPA (U.S. Environmental Protection Agency). (2002). A review of the reference dose and reference concentration processes [EPA Report]. (EPA630P02002F). Washington, DC. https://www.epa.gov/sites/production/files/2014-12/documents/rfd-final.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2011). Recommended use of body weight 3/4 as the default method in derivation of the oral reference dose. (EPA100R110001). Washington, DC. https://www.epa.gov/sites/production/files/2013-09/documents/recommended-use-of-bw34.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2012). Benchmark dose technical guidance [EPA Report]. (EPA100R12001). Washington, DC: U.S. Environmental Protection Agency, Risk Assessment Forum. https://www.epa.gov/risk/benchmark-dose-technical-guidance.
U.S. EPA (U.S. Environmental Protection Agency). (2018). Chemistry Dashboard. Washington, DC. Retrieved from https://comptox.epa.gov/dashboard
U.S. EPA (U.S. Environmental Protection Agency). (2019a). Nafion. https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2811.
U.S. EPA (U.S. Environmental Protection Agency). (2019b). PFAS 150. https://heronet.epa.gov/heronet/index.cfm/project/page/project_id/2826.
U.S. EPA (U.S. Environmental Protection Agency). (2020). PFAS 150 (2020) downloads. https://hawc.epa.gov/assessment/100500085/downloads/.
U.S. EPA (U.S. Environmental Protection Agency). (2021a). CompTox Chemicals Dashboard: Perfluoropropanoic acid 422-64-0 | DTXSID8059970. https://comptox.epa.gov/dashboard/dsstoxdb/results?search=DTXSID8059970.
U.S. EPA (U.S. Environmental Protection Agency). (2021b). Health Assessment Workspace Collaborative (HAWC) [Database]. Washington, DC. Retrieved from https://hawc.epa.gov/portal/
U.S. EPA (U.S. Environmental Protection Agency). (2021c). Human health toxicity values for hexafluoropropylene oxide (HFPO) dimer acid and its ammonium salt (CASRN 13252-13-6 and CASRN 62037-80-3). Also known as “GenX chemicals.” Final report [EPA Report]. (EPA-822R-21-010). Washington, DC: U.S. Environmental Protection Agency, Office of Water.
U.S. EPA (U.S. Environmental Protection Agency). (2022a). IRIS toxicological review of perfluorobutanoic acid and related salts [EPA Report]. (EPA/635/R-22/277Fa). Washington, D.C.: U.S. Environmental Protection Agency :: U.S. EPA. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0701tr.pdf.
U.S. EPA (U.S. Environmental Protection Agency). (2022b). ORD staff handbook for developing IRIS assessments [EPA Report]. (EPA 600/R-22/268). Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Center for Public Health and Environmental Assessment. https://cfpub.epa.gov/ncea/iris_drafts/recordisplay.cfm?deid=356370.
U.S. EPA (U.S. Environmental Protection Agency). (2023). IRIS toxicological review of perfluorohexanoic acid [PFHxA, CASRN 307-24-4] and related salts [EPA Report]. (EPA/635/R-23/027Fa). Washington, D.C.: U.S. Environmental Protection Agency :: U.S. EPA. https://iris.epa.gov/ChemicalLanding/&substance_nmbr=704.
U.S. EPA (U.S. Environmental Protection Agency). (2024a). 6:2 FTS downloads. https://hawc.epa.gov/assessment/100500285/downloads/.
U.S. EPA (U.S. Environmental Protection Agency). (2024b). Final Human health toxicity assessment for perfluorooctane sulfonic acid (PFOS) and related salts [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division.
U.S. EPA (U.S. Environmental Protection Agency). (2024c). Final human health toxicity assessment for perfluorooctanoic acid (PFOA) and related salts [EPA Report]. Washington, DC: U.S. Environmental Protection Agency, Office of Water, Health and Ecological Criteria Division.
Woodlief, T; Vance, S; Hu, Q; Dewitt, J. (2021). Immunotoxicity of per- and polyfluoroalkyl substances: Insights into short-chain PFAS exposure. Toxics 9: 100. 10.3390/toxics9050100.34062743
Yan, S; Wang, J; Zhang, W; Dai, J. (2014). Circulating microRNA profiles altered in mice after 28 d exposure to perfluorooctanoic acid. Toxicol Lett 224: 24–31. 10.1016/j.toxlet.2013.10.017.24459700
Yang, L; Li, J; Lai, J; Luan, H; Cai, Z; Wang, Y; Zhao, Y; Wu, Y. (2016). Placental transfer of perfluoroalkyl substances and associations with thyroid hormones: Beijing prenatal exposure study. Sci Rep 6: 21699. 10.1038/srep21699.26898235
Yost, EE; Euling, SY; Weaver, JA; Beverly, BEJ; Keshava, N; Mudipalli, A; Arzuaga, X; Blessinger, T; Dishaw, L; Hotchkiss, A; Makris, SL. (2019). Hazards of diisobutyl phthalate (DIBP) exposure: A systematic review of animal toxicology studies [Review]. Environ Int 125: 579–594. 10.1016/j.envint.2018.09.038.30591249
Zhang, J; Ren, ZM; Chen, M. (2023). Immunotoxicity and transcriptome analyses of zebrafish (Danio rerio) embryos exposed to 6:2 FTSA. Toxics 11: 459. 10.3390/toxics11050459.37235273